# Listing of Excluded Studies

1 Using guidelines to change clinical practice: three case studies. HMO Practice 1996; 10(1): 30–36. Study design did not meet criteria for RCT, CBA, or ITS
2 Anokbonggo WW, Ogwal-Okeng J. W. Obua C. Aupont O. Ross-Degnan D. Impact of decentralization on health services in Uganda: a look at facility utilization, prescribing and availability of essential drugs. East African Medical Journal 2004:S2. Study design did not meet criteria for RCT, CBA, or ITS
3 Anonymous. North of England study of standards and performance in general practice. An overview of the study. Report no 50. Centre for Health Services Research, Ambulatory Care Programme 1991. Overlaps with or duplicates another article that was included
4 Anonymous. Medical audit in general practice. II: Effects on health of patients with common childhood conditions. North of England Study of Standards and Performance in General Practice. BMJ 1992; 304:1484. Other
5 Anonymous. Changing prescribing practices. Medicine Today 2001; 2:14. Not an evaluation of a QI intervention
6 Barwitz HJ. Sore throat consultation—what is the value of a treatment guideline? German Original Beratungsanlass Halsschmerzen—was nutzt eine Handlungsleitlinie?. MMW Fortschritte der Medizin. 1999;141:32. Foreign language article article.
7 Barwitz HJK. Common cold - Trial to rationalize management in general practice by recommendation. Zeitschrift fur Allgemeinmedizin. 1999;71(2122):932. Foreign language article article.
8 Batchelor B, Crook DW, Jones T, Bowler IC. Impact of guidelines for the diagnosis of urinary tract infection on trimethoprim susceptibility of Escherichia coli. Journal of Antimicrobial Chemotherapy. 2002;49:223. Not an evaluation of a QI intervention. [pmid: 11751797].
9 Beardon PH, Brown SV, Mowat DA, et al. Introducing a drug formulary to general practice—effects on practice prescribing costs. Journal of the Royal College of General Practitioners. 1987;37:305. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 3449632]. [pmcid: 1710912].
10 Bowler IC, Atkins BL, Batchelor BI, et al. Impact of guidelines for the diagnosis of UTI letter; see comments. British Journal of General Practice. 1998;48:1790. No eligible outcomes. [pmid: 10198495].
11 Brook RH, Williams KN. Effect of medical care review on the use of injections: a study of the New Mexico Experimental Medical Care Review Organization. Annals of Internal Medicine. 1976;85:509. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 989709].
12 Burr A. Impact of fundholding on general practice prescribing patterns. Pharmaceutical Journal. 1992; 249 R8. No eligible outcomes
13 Chalker J. Improving antibiotic prescribing in Hai Phong Province, Viet Nam: the “antibiotic-dose” indicator. Bulletin of the World Health Organization. 2001;79:313. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11357210].
14 Chiefari DM. Effect of a closed formulary on average prescription cost in a community health center. Drug Benefit Trends. 2001;13:45-52. Study design did not meet criteria for RCT, CBA, or ITS.
15 Chowdhury AKA, et al. Effect of standard treatment guidelines with or without audit on prescribing for acute respiratory infections in government health facilities in Bangladesh. International Network for Rational Use of Drugs 1996. Article not available
16 Cohen R, Allaert FA, Callens A, et al. Medico-economic evaluation of an educational intervention to optimize children uncomplicated nasopharyngitis treatment in ambulatory care. Medecine et Maladies Infectieuses. 2000;30:691. Foreign language article.
17 de Silva MI, Mize GN, Rissing JP. Peer review of antibiotic use: positive impact on physician prescribing patterns. Qrb 1985; QualityReviewBulle:302. Study design did not meet criteria for RCT, CBA, or ITS
18 Dickey FF, Mattar ME, Chudzik GM. Pharmacist counsling increases drug regimen compliance. Hospitals. 1988;49:85-86. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 47833].
19 Doyne EO, Alfaro MP, Siegel RM, et al. A randomized controlled trial to change antibiotic prescribing patterns in a community. Arch Pediatr Adolesc Med. 2004;158:577-83. Other. [pmid: 15184222].
20 Du B, Chen D, Liu D, Long Y, Shi Y, Wang H, Rui X, Cui N. Restriction of third-generation cephalosporin use decreases infection-related mortality. A controlled trial of a critical pathway for treating community-acquired pneumonia: the CAPITAL study Community-Acquired Pneumonia Intervention Trial Assessing Levofloxacin. Critical Care Medicine. 2003;31:1088. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 12682477].
21 Ekedahl A, Andersson SI, Hovelius B, Molstad S, Liedholm H, Melander A. Drug prescription attitudes and behaviour of general practitioners. Effects of a problem-oriented educational programme. European Journal of Clinical Pharmacology. 1995;47(5):381. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 7720757].
22 Evans RS, Classen DC, Pestotnik SL, et al. Improving empiric antibiotic selection using computer decision support. Archives of Internal Medicine. 1994;154:878. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 8154950].
23 Finney JW, Friman PC, Rapoff MA, et al. Improving compliance with antibiotic regimens for otitis media. Randomized clinical trial in a pediatric clinic. American Journal of Diseases of Children. 1985;139:89-95. No eligible outcomes. [pmid: 3881932].
24 Font M, Madridejos R, Catalan A, et al. Improving drug prescription in primary care: a controlled and randomized study of an educational method. Spanish. Medicina Clinica. 1991;96:201. Foreign language article.
25 Friis H, Bro F, Mabeck CE, et al. An information campaign—an important measure in controlling the use of antibiotics. Journal of Antimicrobial Chemotherapy. 1989;24:993. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 2621182].
26 Friis H, Bro F, Eriksen NR, et al. The effect of reimbursement on the use of antibiotics. Scandinavian Journal of Primary Health Care. 1993;11:247. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 8146508].
27 Garcia Lirola MA, Cabeza Barrera J, Lirola Garcia E. Intervention to improve the quality of antibacterial drug prescribing practices in primary care. Farmacia Hospitalaria. 1999;23:42. Foreign language article.
28 Gonzales R, Steiner JF, Maselli J, et al. Impact of reducing antibiotic prescribing for acute bronchitis on patient satisfaction. see comments. Effective Clinical Practice. 2001;4:105. No eligible outcomes. [pmid: 11434073].
29 Gonzales R, Sauaia A, Corbett KK, et al. Antibiotic treatment of acute respiratory tract infections in the elderly: effect of a multidimensional educational intervention. Journal of the American Geriatrics Society. 2004;52:39. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 14687313].
30 Goode CJ, Tanaka DJ, Krugman M, et al. Outcomes from use of an evidence-based practice guideline. Nursing Economics. 2000;18:202. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11061158].
31 Gordis L. Evaluation of the effectiveness of comprehensive and continuous pediatric care. Pediatrics. 1971;48:766. Not an evaluation of a QI intervention. [pmid: 5121237].
32 Greenfield S, Friedland G, Scifers S, et al. Protocol management of dysuria, urinary frequency, and vaginal discharge. Annals of Internal Medicine. 1974;81:452. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 4415356].
33 Gregory C, Cifaldi M, Tanner LA. Targeted intervention programs: creating a customized practice model to improve the treatment of allergic rhinitis in a managed care population. American Journal of Managed Care. 1999;5:485. Other. [pmid: 10387387].
34 Guiscafre H, Martinez H, Reyes H, et al. From research to public health interventions. I. Impact of an educational strategy for physicians to improve treatment practices of common diseases. Archives of Medical Research. 1995;26:S31. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 8845656].
35 Gupta D, Mishra S, Chaturvedi P. ARI Control Programme: standard case management guidelines vs conventional treatment—an open study. Indian Pediatrics. 1996;33:41-43. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 8772951].
36 Gurwitz JH, McLaughlin TJ, Fish LS. The effect of an Rx-to-OTC switch on medication prescribing patterns and utilization of physician services: the case of vaginal antifungal products. Health Services Research. 1995;30:672. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 8537226]. [pmcid: 1070084].
37 Harris CM, Jarman B, Woodman E, et al. Prescribing—a suitable case for treatment. J R Coll Gen Pract. 1984;24:1-39. Other.
38 Harris CM, Fry J, Jarman B, et al. Prescribing—a case for prolonged treatment. J R Coll Gen Pract. 1985;35:284-7. Other. [pmid: 4032356]. [pmcid: 1960020].
39 Harris RH, MacKenzie TD, Leeman-Castillo B, et al. Optimizing antibiotic prescribing for acute respiratory tract infections in an urban urgent care clinic. J Gen Intern Med. 2003;18:326-34. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12795730]. [pmcid: 1494862].
40 Hastings JE, Mott FD, Barclay A, et al. Prepaid group practice in Sault Ste. Marie, Ontario. I. Analysis of utilization records. Medical Care. 1973;11:91. Not an evaluation of a QI intervention. [pmid: 4688484].
41 Hemeryck L, McGettigan P, Feely J. Hospital antibiotic prescribing and feedback [letter; comment]. British Journal of Clinical Pharmacology. 1997;43:449-450. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9146861].
42 Hueston WJ, Mainous AG 3rd, Brauer N, et al. Evaluation and treatment of respiratory infections: does managed care make a difference?. Journal of Family Practice. 1997;44:572. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9191630].
43 Ives T, et al. Effect of an educational intervention on oral cephalosporin use in primary care. Arch Internal Med. 1987;147:44-47. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3492181].
44 Jacobs B, Kambugu FS, Whitworth JA, Ochwo M, Pool R, Lwanga A, Tifft S, Lule J, Cutler JR. Social marketing of pre-packaged treatment for men with urethral discharge (Clear Seven) in Uganda. International Journal of STD & AIDS. 2003;14:216. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12665447].
45 Juncosa S, Porta M. Effects of primary health care reform on the prescription of antibiotics: A longitudinal study in a Spanish county. European Journal of Public Health. 1997;7:54. Other.
46 Kafle KK. Intervention test of training supervision on prescribing practices. 1995. Article not available
47 Kinney WC. Rhinosinusitis treatment protocol: changing provider habits in primary care. Otolaryngology Head & Neck Surgery. 2002;126:614. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12087327].
48 Leach RH, Wakeman A. An evaluation of the effectiveness of community pharmacists working with GPs to increase the cost-effectiveness of prescribing. Pharmaceutical Journal. 1999;263:206. Study design did not meet criteria for RCT, CBA, or ITS.
49 Lundborg CS, Tomson G, Wahlstrom R, et al. GPs' knowledge and attitudes regarding treatment of UTI and asthma in Sweden: A randomised controlled educational trial on guideline implementation. European Journal of Public Health. 2000;10:246. No eligible outcomes.
50 Margolis CZ, Warshawsky SS, Goldman L, et al. Computerized algorithms and pediatricians' management of common problems in a community clinic. Academic Medicine. 1992;67:282. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 1558607].
51 Mather JL, Bayliff CD, Reider MJ, et al. The impact of formulary reservations on drug utilization: a controlled trial. Canadian Journal of Hospital Pharmacy. 1994;47:111-116. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10135645].
52 Molstad S, Ekedahl. Antibiotics prescription in primary care: A 5-year follow-up of an educational programme. Family Practice. 1994;11:282-286. Other. [pmid: 7843518].
53 Mtango F, Neuvians D. Acute respiratory infections in children under five years. Control project in Bagamoyo District, Tanzania. Trans Roy Soc Trop Med Hyg. 1986;80:851. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 3603635].
54 Munck AP, Gahrn-Hansen B, Sogaard P, et al. Long-lasting improvement in general practitioners' prescribing of antibiotics by means of medical audit. Scandinavian Journal of Primary Health Care. 1999;17:185-190. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10555250].
55 Naivalulevu L. Training for rational drug use (prescriptions of antibiotics for coughs and colds in Fiji has been greatly reduced since health staff participated in training workshops). ARI News 1990; 19. Study design did not meet criteria for RCT, CBA, or ITS
56 Needham A. Introduction and audit of a general practice antibiotic formulary. J Royal College of General Practitioners. 1988;38:166. Study design did not meet criteria for RCT, CBA, or ITS.
57 Newby DA, Fryer JL, Henry DA. Effect of computerised prescribing on use of antibiotics. comment. Medical Journal of Australia. 2003;178:210. Not an evaluation of a QI intervention. [pmid: 12603183].
58 Obua C, Ogwal-Okeng JW, Waako P, Aupont O, Ross-Degnan D. Impact of an educational intervention to improve prescribing by private physicians in Uganda. East African Medical Journal 2004:S17. Other
59 Ornstein SM, MacFarlane LL, Jenkins RG, et al. Medication cost information in a computer-based patient record system. Impact on prescribing in a family medicine clinical practice. Archives of Family Medicine. 1999;8:118-121. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10101981].
60 Palmer NA, Dailey YM, Martin MV. Can audit improve antibiotic prescribing in general dental practice?. British Dental Journal. 2001;191:253. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11575760].
61 Paredes SP, et al. Intervention trial to decrease the inappropriate use of drugs during childhood diarrhoea. 2003. Article not available
62 Perez Rodriguez MT, Catalan Ramos A, Parellada Esquius N. Criteria for the development of a formulary of drugs in a basic health area and impact on prescription (published erratum appears in Aten Primaria. 1995 Mar 15;15(4):270) Spanish. Atencion Primaria. 1994;14:1128. Foreign language article. [pmid: 7849214].
63 Perez-Cuevas R, Guiscafre H, Munoz O, et al. Improving physician prescribing patterns to treat rhinopharyngitis. Intervention strategies in two health systems of Mexico. Social Science & Medicine. 1996;42:1185. Other. [pmid: 8737437].
64 Poses RM, Cebul RD, Wigton RS. You can lead a horse to water—improving physicians' knowledge of probabilities may not affect their decisions published erratum appears in Med Decis Making 1995 Apr–Jun;15(2):179. Medical Decision Making 1995; 15:65. Study design did not meet criteria for RCT, CBA, or ITS
65 Putnam W, Curry L. Patient care appraisal in the ambulatory setting: effectiveness as a continuing medical education tool. Annual Conference on Research in Medical Education. 1980;19:207. No eligible outcomes. [pmid: 7458202].
66 Qazi SA, Rehman GN, Khan MA. Standard management of acute respiratory infections in a children's hospital in Pakistan: impact on antibiotic use and case fatality. Bulletin World Health Organization. 1996;74(5):501-7. Study design did not meet criteria for RCT, CBA, or ITS.
67 Ray WA, Schaffner W, Federspiel CF. Persistence of improvement in antibiotic prescribing in office practice. JAMA. 1985;253:1774. Overlaps with or duplicates another article that was included. [pmid: 3974058].
68 Ray WA, Fink R, Schaffner W, et al. Improving antibiotic prescribing in outpatient practice. Nonassociation of outcome with prescriber characteristics and measures of receptivity. Medical Care. 1985;23:1307. Other. [pmid: 4068797].
69 Rosser W, Dunn L, Pilla J, et al. Using academic detailing to disseminate clinical practice guidelines [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care. 1997;13:93. Abstract; article not available.
70 Saint S, Scholes D, Fihn SD, et al. The effectiveness of a clinical practice guideline for the management of presumed uncomplicated urinary tract infection in women. American Journal of Medicine. 1999;106:636-641. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10378621].
71 Seppälä H, Klaukka T, Vuopio-Varkila J, et al. The Effect of Changes in the Consumption of Macrolide Antibiotics on Erythromycin Resistance in Group A Streptococci in Finland. N Engl J Med. 1997;337:441-446. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9250845].
72 Sever CM, MacKinnon GE III. Evaluation of a criteria-based anti-infective formulary. P & T. 1993;18:770-776. Study design did not meet criteria for RCT, CBA, or ITS.
73 Shalansky SJ. Antibiotic interchange through educational interventions in a community hospital. American Journal of Hospital Pharmacy. 1991;48:2655-2657. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 1814215].
74 Simon JL, Smith DB. Change in location of a student health service: a quasi-experimental evaluation of the effects of distance on utilization. Medical Care. 1973;11:59. Not an evaluation of a QI intervention. [pmid: 4686968].
75 Soumerai S. Economic and policy analysis of university-based drug “detailing”. Medical Care. 1986;24:313. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3083161].
76 Soumerai S. Predictors of physician prescribing change in an educational experiment to improve medication use. Medical Care. 1987;25:210. Overlaps with or duplicates another article that was included. [pmid: 3821226].
77 Soumerai SB, Avorn J, Taylor WC, et al. Improving choice of prescribed antibiotics through concurrent reminders in an educational order form. Medical Care. 1993;31:552. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 8502003].
78 South M, Royle J, Starr M. A simple intervention to improve hospital antibiotic prescribing. comment. Medical Journal of Australia. 2003;178:207. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12603182].
79 Stewart J, Pilla J, Dunn L. Pilot study for appropriate anti-infective community therapy. Effect of a guideline-based strategy to optimize use of antibiotics. Canadian Family Physician. 2000;46:851. Other. [pmid: 10790817]. [pmcid: 2144801].
80 Stuart ME, Macuiba J, Heidrich F, et al. Successful implementation of an evidence-based clinical practice guideline: acute dysuria/urgency in adult women. HMO Practice. 1997;11:150. No eligible outcomes. [pmid: 10176516].
81 Suchyta MR, Dean NC, Narus S, et al. Effects of a practice guideline for community-acquired pneumonia in an outpatient setting. American Journal of Medicine. 2001;110:306. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11239849].
82 Temte JL, Shult PA, Kirk CJ, et al. Effects of viral respiratory disease education and surveillance on antibiotic prescribing. Family Medicine. 1999;31:101. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9990499].
83 Thamer M, Ray NF, Henderson SC, et al. Influence of the NIH Consensus Conference on Helicobacter pylori on physician prescribing among a Medicaid population. Medical Care. 1998;36:646. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 9596056].
84 Tierney W, Hui SL, McDonald CJ. Delayed feedback of physician performance versus immediate reminders to perform preventive care. Effects on physician compliance. Medical Care. 1986;24:659. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 3736141].
85 Tseng R. An audit of antibiotic prescribing in general practice using sore throats as a tracer for quality control. Public Health. 1985;99:177. Study design did not meet criteria for RCT, CBA, or ITS.
86 Tumwikirize WA, Ekwaru PJ, Mohammed K, et al. Impact of a face-to-face educational intervention on improving the management of acute respiratory infections in private pharmacies and drug shops in Uganda. East Afr Med J. 2004; Suppl:S25–32. Excluded topic (focused on inpatient care or antimicrobial use in chronic care)
87 Wahlstrom R, Kounnavong S, Sisounthone B, Phanyanouvong A, Southammavong T, Eriksson B, Tomson G. Effectiveness of feedback for improving case management of malaria, diarrhoea and pneumonia—a randomized controlled trial at provincial hospitals in Lao PDR. Tropical Medicine & International Health. 2003;8:901. No eligible outcomes. [pmid: 14516301].
88 Walley T, Murphy M, Codd M, et al. Effects of a monetary incentive on primary care prescribing in Ireland: changes in prescribing patterns in one health board 1990-1995. Pharmacoepidemiology & Drug Safety. 2000;9:591. No eligible outcomes. [pmid: 11338918].
89 Williams M. Evaluation of patient counselling on the use of antibiotics in community pharmacies. Article not available
90 Wilson RG, Bojke C, O'Neill S, et al. Designing, specifying and evaluating a new repeat prescribing process for UK general practice. Studies in Health Technology & Informatics. 2000;77:219. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 11187545].
91 Wilson SD, Dahl BB, Wells RD. An evidence-based clinical pathway for bronchiolitis safely reduces antibiotic overuse. American Journal of Medical Quality. 2002;17:195. Excluded topic (focused on inpatient care or antimicrobial use in chronic care). [pmid: 12412948].
92 Zwar NA, Gordon JJ, Sanson-Fisher RW. Evaluation of an educational program in rational prescribing for GP trainees. Australian Family Physician. 1995;24:833. Other. [pmid: 7794146].
93 Zwar N, Henderson J, Britt H, et al. Influencing antibiotic prescribing by prescriber feedback and management guidelines: a 5-year follow-up. Family Practice. 2002;19:12. Other. [pmid: 11818344].