# Summary Tables

Table 1A. QI strategies and outcomes for antibiotic treatment studies.

Table 1B. QI strategies and outcomes for antibiotic selection studies.

Table 1C. Antibiotic treatment studies: target condition and population.

Table 1D. Antibiotic selection studies: target condition and population.

Table 2. Antibiotic treatment studies: number of QI strategies utilized.

Table 3. Median effect size of QI strategies on antibiotic treatment decision.

Table 4. Antibiotic treatment studies: QI strategies and study modifiers.

Table 5. Results of Wilcoxon rank-sum tests for differences between groups.

Table 6. Delayed prescription studies.

Table 7. Antibiotic selection studies: number of QI strategies utilized.

Table 8. Median effect size of QI strategies on antibiotic selection decision.

Table 9. Selection studies: QI strategies and study modifiers.