# References

1 Shojania K, Ranji S, Shaw LK, Charo LN, Lai JC, Rushakoff RJ, McDonald KM, Owens DK. Closing The Quality Gap: A Critical Analysis Of Quality Improvement Strategies, Volume 2 - Diabetes Mellitus Care. AHRQ Publication No. 04-0051-2. Rockville, MD: Agency for Healthcare Research and Quality. 2004.
2 Walsh J, McDonald KM, Shojania KG, Sundaram V, Lewis R, Nayak S, Mechanic J, Owens DK, Goldstein MK. Closing The Quality Gap: A Critical Analysis Of Quality Improvement Strategies, Volume 3 - Hypertension Care. AHRQ Publication No. 04-0051-3. Rockville, MD: Agency for Healthcare Research and Quality. 2005.
3 Cohen ML. Epidemiology of drug resistance: implications for a post-antimicrobial era. Science. 1992;257(5073):1050-1055. [pmid: 1509255].
4 Levy SB. Confronting multidrug resistance. A role for each of us. Jama. 1993;269(14):1840-1842. [pmid: 8459518].
5 Whitney CG, Farley MM, Hadler J, et al. Increasing prevalence of multidrug-resistant Streptococcus pneumoniae in the United States. N Engl J Med. 2000;343(26):1917-1924. [pmid: 11136262].
6 Doern GV, Brueggemann AB, Huynh H, Wingert E. Antimicrobial resistance with Streptococcus pneumoniae in the United States, 1997 98. Emerg Infect Dis. 1999;5(6):757-765. [pmid: 10603208].
7 Chen DK, McGeer A, de Azavedo JC, Low DE. Decreased susceptibility of Streptococcus pneumoniae to fluoroquinolones in Canada. Canadian Bacterial Surveillance Network. N Engl J Med. 1999;341(4):233-239. [pmid: 10413735].
8 Herold BC, Immergluck LC, Maranan MC, et al. Community-acquired methicillin-resistant Staphylococcus aureus in children with no identified predisposing risk. Jama. 1998;279(8):593-598. [pmid: 9486753].
9 Akram J, Glatt AE. True community-acquired methicillin-resistant Staphylococcus aureus bacteremia. Infect Control Hosp Epidemiol. 1998;19(2):106-107. [pmid: 9510108].
10 Gupta K, Hooton TM, Wobbe CL, Stamm WE. The prevalence of antimicrobial resistance among uropathogens causing acute uncomplicated cystitis in young women. Int J Antimicrob Agents. 1999;11(34):305-308. [pmid: 10394988].
11 Marco CA, Parker K. Antimicrobial resistance among organisms causing urinary tract infections. Acad Emerg Med. 1997;4(2):159-160. [pmid: 9043549].
12 Wright SW, Wrenn KD, Haynes ML. Trimethoprim-sulfamethoxazole resistance among urinary coliform isolates. J Gen Intern Med. 1999;14(10):606-609. [pmid: 10571705]. [pmcid: 1496756].
13 Doone JL, Klespies SL, Sabella C. Risk factors for penicillin-resistant systemic pneumococcal infections in children. Clin Pediatr (Phila). 1997;36(4):187-191. [pmid: 9114988].
14 Hofmann J, Cetron MS, Farley MM, et al. The prevalence of drug-resistant Streptococcus pneumoniae in Atlanta. N Engl J Med. 1995;333(8):481-486. [pmid: 7623880].
15 Moreno F, Crisp C, Jorgensen JH, Patterson JE. The clinical and molecular epidemiology of bacteremias at a university hospital caused by pneumococci not susceptible to penicillin. J Infect Dis. 1995;172(2):427-432. [pmid: 7622885].
16 Nava JM, Bella F, Garau J, et al. Predictive factors for invasive disease due to penicillin-resistant Streptococcus pneumoniae: a population-based study. Clin Infect Dis. 1994;19(5):884-890. [pmid: 7893874].
17 Newby D, A. Fryer JL, Henry DA. Effect of computerised prescribing on use of antibiotics. comment. Medical Journal of Australia. 2003;178(5):210. [pmid: 12603183].
18 Chesney PJ, Davis Y, English BK, Wang WC. Occurrence of Streptococcus pneumoniae meningitis during vancomycin and cefotaxime therapy of septicemia in a patient with sickle cell disease. Pediatr Infect Dis J. 1995;14(11):1013-1015. [pmid: 8584345].
19 Friedland IR, Klugman KP. Failure of chloramphenicol therapy in penicillin-resistant pneumococcal meningitis. Lancet. 1992;339(8790):405-408. [pmid: 1346668].
20 Lonks JR, Durkin MR, Meyerhoff AN, Medeiros AA. Meningitis due to ceftriaxone-resistant Streptococcus pneumoniae. N Engl J Med. 1995;332(13):893-894. [pmid: 7870156].
21 Radetsky MS, Istre GR, Johansen TL, et al. Multiply resistant pneumococcus causing meningitis: its epidemiology within a day-care centre. Lancet. 1981;2(8250):771-773. [pmid: 6116903].
22 Reid R Jr, Bradley JS, Hindler J. Pneumococcal meningitis during therapy of otitis media with clarithromycin. Pediatr Infect Dis J. 1995;14(12):1104-1105. [pmid: 8786899].
23 Pallares R, Viladrich PF, Linares J, Cabellos C, Gudiol F. Impact of antibiotic resistance on chemotherapy for pneumococcal infections. Microb Drug Resist. 1998;4(4):339-347. [pmid: 9988053].
24 Poole MD. Otitis media complications and treatment failures: implications of pneumococcal resistance. Pediatr Infect Dis J. 1995;14(4 Suppl):S23-26. [pmid: 7792127].
25 Bradley JS, Kaplan SL, Klugman KP, Leggiadro RJ. Consensus: management of infections in children caused by Streptococcus pneumoniae with decreased susceptibility to penicillin. Pediatr Infect Dis J. 1995;14(12):1037-1041. [pmid: 8745014].
26 Feikin DR, Schuchat A, Kolczak M, et al. Mortality from invasive pneumococcal pneumonia in the era of antibiotic resistance, 1995-1997. Am J Public Health. 2000;90(2):223-229. [pmid: 10667183]. [pmcid: 1446155].
27 Metlay JP, Hofmann J, Cetron MS, et al. Impact of penicillin susceptibility on medical outcomes for adult patients with bacteremic pneumococcal pneumonia. Clin Infect Dis. 2000;30(3):520-528. [pmid: 10722438].
28 Bartlett JG, Dowell SF, Mandell LA, File TM Jr, Musher DM, Fine MJ. Practice guidelines for the management of community-acquired pneumonia in adults. Infectious Diseases Society of America. Clin Infect Dis. 2000;31(2):347-382. [pmid: 10987697].
29 Niederman MS, Mandell LA, Anzueto A, et al. Guidelines for the management of adults with community-acquired pneumonia. Diagnosis, assessment of severity, antimicrobial therapy, and prevention. Am J Respir Crit Care Med. 2001;163(7):1730-1754. [pmid: 11401897].
30 Hyde TB, Gay K, Stephens DS, et al. Macrolide resistance among invasive Streptococcus pneumoniae isolates. Jama. 2001;286(15):1857-1862. [pmid: 11597287].
31 Kunin CM. Resistance to antimicrobial drugs—a worldwide calamity. Ann Intern Med. 1993;118(7):557-561. [pmid: 8442626].
32 Neu HC. The crisis in antibiotic resistance. Science. 1992;257(5073):1064-1073. [pmid: 1509257].
33 McCormick AW, Whitney CG, Farley MM, et al. Geographic diversity and temporal trends of antimicrobial resistance in Streptococcus pneumoniae in the United States. Nat Med. 2003;9(4):424-430. [pmid: 12627227].
34 Lipsitch M, Samore MH. Antimicrobial use and antimicrobial resistance: a population perspective. Emerg Infect Dis. 2002;8(4):347-354. [pmid: 11971765].
35 Lipsitch M. The rise and fall of antimicrobial resistance. Trends Microbiol. 2001;9(9):438-444. [pmid: 11553456].
36 Seppälä H, Klaukka T, Vuopio-Varkila J, et al. The Effect of Changes in the Consumption of Macrolide Antibiotics on Erythromycin Resistance in Group A Streptococci in Finland. N Engl J Med. 1997;337:441-446. [pmid: 9250845].
37 Doern GV, Heilmann KP, Huynh HK, Rhomberg PR, Coffman SL, Brueggemann AB. Antimicrobial resistance among clinical isolates of Streptococcus pneumoniae in the United States during 1999-2000, including a comparison of resistance rates since 1994-1995. Antimicrob Agents Chemother. 2001;45(6):1721-1729. [pmid: 11353617]. [pmcid: 90537].
38 Gonzales R, Steiner JF, Sande MA. Antibiotic prescribing for adults with colds, upper respiratory tract infections, and bronchitis by ambulatory care physicians. Jama. 1997;278(11):901-904. [pmid: 9302241].
39 Mainous AG 3rd, Hueston WJ, Davis MP, Pearson WS. Trends in antimicrobial prescribing for bronchitis and upper respiratory infections among adults and children. Am J Public Health. 2003;93(11):1910-1914. [pmid: 14600065]. [pmcid: 1448075].
40 McCaig LF, Besser RE, Hughes JM. Antimicrobial drug prescription in ambulatory care settings, United States, 1992-2000. Emerg Infect Dis. 2003;9(4):432-437. [pmid: 12702222].
41 Steinman MA, Gonzales R, Linder JA, Landefeld CS. Changing use of antibiotics in community-based outpatient practice, 1991-1999. Ann Intern Med. 2003;138(7):525-533. [pmid: 12667022].
42 Jernigan DB, Cetron MS, Breiman RF. Minimizing the impact of drug-resistant Streptococcus pneumoniae (DRSP). A strategy from the DRSP Working Group. Jama. 1996;275(3):206-209. [pmid: 8604173].
43 Institute of Medicine. Antimicrobial Resistance: Issues and Options. Harrison PF and Lederberg J, eds. National Academy Press. 1998.
44 Centers for Disease Control. Public Health Action Plan to Combat Antimicrobial Resistance. Available online at: http://www.cdc.gov/drugresistance/actionplan/html/index.htm. Accessed March 10, 2005.
45 National Committee for Quality Assurance Health Plan and Employer Data Information Set (HEDIS). www.ncqa.org, accessed 7.1.2005.
46 Vander Stichele RH, Elseviers MM, Ferech M, Blot S, Goossens H. European surveillance of antimicrobial consumption (ESAC): data collection performance and methodological approach. Br J Clin Pharmacol. 2004;58(4):419-428. [pmid: 15373935]. [pmcid: 1884596].
47 Institute of Medicine. Priority Areas for National Action: Transforming Health Care Quality. Adams K and Corrigan JM, eds. National Academy Press. 2003.
48 Bero LA, Grilli R, Grimshaw JM, Harvey E, Oxman AD, Thomson MA. Closing the gap between research and practice: an overview of systematic reviews of interventions to promote the implementation of research findings. The Cochrane Effective Practice and Organization of Care Review Group. Bmj. 1998;317(7156):465-468. [pmid: 9703533]. [pmcid: 1113716].
49 Grimshaw JM, Shirran L, Thomas R, et al. Changing provider behavior: an overview of systematic reviews of interventions. Med Care. 2001;39(8 Suppl 2):II2-45. [pmid: 11583120].
50 Oxman AD, Thomson MA, Davis DA, Haynes RB. No magic bullets: a systematic review of 102 trials of interventions to improve professional practice. Cmaj. 1995;153(10):1423-1431. [pmid: 7585368]. [pmcid: 1487455].
51 Shojania KG, Grimshaw JM. Evidence-based quality improvement: the state of the science. Health Aff (Millwood). 2005;24(1):138-150. [pmid: 15647225].
52 Kleinman A, Eisenberg L, Good B. Culture, illness, and care: clinical lessons from anthropologic and cross-cultural research. Ann Intern Med. 1978;88(2):251-258. [pmid: 626456].
53 Vinson DC, Lutz LJ. The effect of parental expectations on treatment of children with a cough: a report from ASPN. J Fam Pract. 1993;37(1):23-27. [pmid: 8345335].
54 Bauchner H, Pelton SI, Klein JO. Parents, physicians, and antibiotic use. Pediatrics. 1999;103(2):395-401. [pmid: 9925831].
55 Hamm RM, Hicks RJ, Bemben DA. Antibiotics and respiratory infections: are patients more satisfied when expectations are met?. J Fam Pract. 1996;43(1):56-62. [pmid: 8691181].
56 Cockburn J, Pit S. Prescribing behaviour in clinical practice: patients' expectations and doctors' perceptions of patients' expectations—a questionnaire study. Bmj. 1997;315(7107):520-523. [pmid: 9329308]. [pmcid: 2127349].
57 Mangione-Smith R, McGlynn EA, Elliott MN, Krogstad P, Brook RH. The relationship between perceived parental expectations and pediatrician antimicrobial prescribing behavior. Pediatrics. 1999;103(4 Pt 1):711-718. [pmid: 10103291].
58 Macfarlane J, Holmes W, Macfarlane R, Britten N. Influence of patients' expectations on antibiotic management of acute lower respiratory tract illness in general practice: questionnaire study. Bmj. 1997;315(7117):1211-1214. [pmid: 9393228]. [pmcid: 2127752].
59 Gonzales R, Corbett KK, Leeman-Castillo BA, et al. The “Minimizing Antibiotic Resistance in Colorado” Project: Impact of Patient Education in Improving Antibiotic Use in Private Office Practices. Health Serv Res. 2005;40(1):101-116. [pmid: 15663704]. [pmcid: 1361128].
60 Nyquist AC, Gonzales R, Steiner JF, Sande MA. Antibiotic prescribing for children with colds, upper respiratory tract infections, and bronchitis. Jama. 1998;279(11):875-877. [pmid: 9516004].
61 Gonzales R, Barrett PH Jr, Steiner JF. The relation between purulent manifestations and antibiotic treatment of upper respiratory tract infections. J Gen Intern Med. 1999;14(3):151-156. [pmid: 10203620]. [pmcid: 1496549].
62 Heald A, Auckenthaler R, Borst F, et al. Adult bacterial nasopharyngitis: a clinical entity?. J Gen Intern Med. 1993;8(12):667-673. [pmid: 8120682].
63 Kaiser L, Lew D, Hirschel B, et al. Effects of antibiotic treatment in the subset of common-cold patients who have bacteria in nasopharyngeal secretions. Lancet. 1996;347(9014):1507-1510. [pmid: 8684101].
64 Mainous AG 3rd, Hueston WJ, Eberlein C. Colour of respiratory discharge and antibiotic use. Lancet. 1997;350(9084):1077. [pmid: 10213556].
65 Mainous AG 3rd, Zoorob RJ, Oler MJ, Haynes DM. Patient knowledge of upper respiratory infections: implications for antibiotic expectations and unnecessary utilization. J Fam Pract. 1997;45(1):75-83. [pmid: 9228917].
66 Robertson AJ. Green sputum. Lancet. 1952;1(1):12-15. [pmid: 14889738].
67 Mainous AG 3rd, Hueston WJ, Love MM. Antibiotics for colds in children: who are the high prescribers?. Arch Pediatr Adolesc Med. 1998;152(4):349-352. [pmid: 9559710].
68 Stone S, Gonzales R, Maselli J, Lowenstein SR. Antibiotic prescribing for patients with colds, upper respiratory tract infections, and bronchitis: A national study of hospital-based emergency departments. Ann Emerg Med. 2000;36(4):320-327. [pmid: 11020678].
69 Steinman MA, Landefeld CS, Gonzales R. Predictors of broad-spectrum antibiotic prescribing for acute respiratory tract infections in adult primary care. Jama. 2003;289(6):719-725. [pmid: 12585950].
70 Linder JA, Stafford RS. Antibiotic treatment of adults with sore throat by community primary care physicians: a national survey, 1989-1999. Jama. 2001;286(10):1181-1186. [pmid: 11559262].
71 Huang ES, Stafford RS. National patterns in the treatment of urinary tract infections in women by ambulatory care physicians. Arch Intern Med. 2002;162(1):41-47. [pmid: 11784218].
72 Gillam SJ. Sociocultural differences in patients' expectations at consultations for upper respiratory tract infection. J R Coll Gen Pract. 1987;37(298):205-206. [pmid: 3694587]. [pmcid: 1710800].
73 Sanchez-Menegay C, Hudes ES, Cummings SR. Patient expectations and satisfaction with medical care for upper respiratory infections. J Gen Intern Med. 1992;7(4):432-434. [pmid: 1506950].
74 Wilson AA, Crane LA, Barrett PH, Gonzales R. Public beliefs and use of antibiotics for acute respiratory illness. J Gen Intern Med. 1999;14(11):658-662. [pmid: 10571713]. [pmcid: 1496766].
75 Gershman K, Leff M, Brand D et al. A statewide survey of antibiotic beliefs and practices for coughs and colds in Colorado. 1st International Conference on Emerging Infectious Diseases. 1998.
76 Gonzales R, Wilson A, Crane LA, Barrett PH Jr. What's in a name? Public knowledge, attitudes, and experiences with antibiotic use for acute bronchitis. Am J Med. 2000;108(1):83-85. [pmid: 11059444].
77 Gonzales R, Steiner JF, Maselli J, Lum A, Barrett PH Jr. Impact of reducing antibiotic prescribing for acute bronchitis on patient satisfaction. see comments. Effective Clinical Practice. 2001;4(3):105. [pmid: 11434073].
78 Cowan PF. Patient satisfaction with an office visit for the common cold. J Fam Pract. 1987;24(4):412-413. [pmid: 3559495].
79 Melnick SL, Sprafka JM, Laitinen DL, Bostick RM, Flack JM, Burke GL. Antibiotic use in urban whites and blacks: the Minnesota Heart Survey. Ann Pharmacother. 1992;26(10):1292-1295. [pmid: 1421657].
80 Arnold KE, Leggiadro RJ, Breiman RF, et al. Risk factors for carriage of drug-resistant Streptococcus pneumoniae among children in Memphis, Tennessee. J Pediatr. 1996;128(6):757-764. [pmid: 8648533].
81 Butler JC, Hofmann J, Cetron MS, Elliott JA, Facklam RR, Breiman RF. The continued emergence of drug-resistant Streptococcus pneumoniae in the United States: an update from the Centers for Disease Control and Prevention's Pneumococcal Sentinel Surveillance System. J Infect Dis. 1996;174(5):986-993. [pmid: 8896499].
82 Schillinger D, Bindman A, Wang F, Stewart A, Piette J. Functional health literacy and the quality of physician-patient communication among diabetes patients. Patient Educ Couns. 2004;52(3):315-323. [pmid: 14998602].
83 Shapiro MF, Ware JE Jr, Sherbourne CD. Effects of cost sharing on seeking care for serious and minor symptoms. Results of a randomized controlled trial. Ann Intern Med. 1986;104(2):246-251. [pmid: 3946953].
84 Stirewalt CF, Linn MW, Godoy G, Knopka F, Linn BS. Effectiveness of an ambulatory care telephone service in reducing drop-in visits and improving satisfaction with care. Med Care. 1982;20(7):739-748. [pmid: 7121093].
85 Arnold SR, Allen UD, Al-Zahrani M, Tan DH, Wang EE. Antibiotic prescribing by pediatricians for respiratory tract infection in children. Clin Infect Dis. 1999;29(2):312-317. [pmid: 10476734].
86 Hutchinson J, Foley RN. Influence of nonmedical factors on antibiotic prescription rates. 37th Interscience Conference on Antimicrobial Agents and Chemotherapy. 1997.
87 Flottorp S, Oxman AD, Havelsrud K, Treweek S, Herrin J. Cluster randomised controlled trial of tailored interventions to improve the management of urinary tract infections in women and sore throat. BMJ. 2002;325:7360.
88 Cochrane Collaboration Effective Practice and Organisation of Care group. Available online at: http://www.epoc.uottawa.ca/register.htm. Accessed March 10, 2005.
89 Juni P, Witschi A, Bloch R, Egger M. The hazards of scoring the quality of clinical trials for meta-analysis. Jama. 1999;282(11):1054-1060. [pmid: 10493204].
90 Maselli JH, Gonzales R. Measuring antibiotic prescribing practices among ambulatory physicians: accuracy of administrative claims data. J Clin Epidemiol. 2001;54(2):196-201. [pmid: 11166536].
91 Grimshaw JM, Thomas RE, MacLennan G, et al. Effectiveness and efficiency of guideline dissemination and implementation strategies. Health Technol Assess. 2004;8(6):iii–iv, 1–72.
92 Campbell MK, Elbourne DR, Altman DG. CONSORT statement: extension to cluster randomised trials. Bmj. 2004;328(7441):702-708. [pmid: 15031246]. [pmcid: 381234].
93 Grimshaw J, McAuley LM, Bero LA, et al. Systematic reviews of the effectiveness of quality improvement strategies and programmes. Qual Saf Health Care. 2003;12(4):298-303. [pmid: 12897365]. [pmcid: 1743751].
94 Torgerson DJ. Contamination in trials: is cluster randomisation the answer?. Bmj. 2001;322(7282):355-357. [pmid: 11159665]. [pmcid: 1119583].
95 Localio AR, Berlin JA, Ten Have TR, Kimmel SE. Adjustments for center in multicenter studies: an overview. Ann Intern Med. 2001;135(2):112-123. [pmid: 11453711].
96 Kerry SM, Bland JM. Sample size in cluster randomisation. Bmj. 1998;316(7130):549. [pmid: 9501723].
97 Donner A, Piaggio G, Villar J. Statistical methods for the meta-analysis of cluster randomization trials. Stat Methods Med Res. 2001;10(5):325-338. [pmid: 11697225].
98 Campbell M, Grimshaw J, Steen N. Sample size calculations for cluster randomised trials. Changing Professional Practice in Europe Group (EU BIOMED II Concerted Action). J Health Serv Res Policy. 2000;5(1):12-16. [pmid: 10787581].
99 Campbell MK, Mollison J, Grimshaw JM. Cluster trials in implementation research: estimation of intracluster correlation coefficients and sample size. Stat Med. 2001;20(3):391-399. [pmid: 11180309].
100 Woodwell DA, Cherry DK. National Ambulatory Medical Care Survey: 2002 summary. Adv Data. 2004(346):1–44.
101 Welschen I, Kuyvenhoven MM, Hoes AW, Verheij TJ. Effectiveness of a multiple intervention to reduce antibiotic prescribing for respiratory tract symptoms in primary care: randomised controlled trial. Bmj. 2004;329(7463):431. [pmid: 15297305]. [pmcid: 514206].
102 Smabrekke L, Berild D, Giaever A, et al. Educational intervention for parents and healthcare providers leads to reduced antibiotic use in acute otitis media. Scand J Infect Dis. 2002;34(9):657-659. [pmid: 12374355].
103 Santoso B, Suryawati S, Prawaitasari JE. Small group intervention vs formal seminar for improving appropriate drug use published erratum appears in Soc Sci Med 1996 Jul;43(1):I. Social Science & Medicine. 1996;42(8):1163. [pmid: 8737434].
104 Molstad S, Hovelius. Reduction in antibiotic usage following an educational programme. Family Practice. 1989;6(1):33-37. [pmid: 2714542].
105 Meyer JC, Summers RS, Moller H. Randomized, controlled trial of prescribing training in a South African province. Med Educ. 2001;35(9):833-840. [pmid: 11555220].
106 Melander E, Bjorgell A, Bjorgell P, Ovhed I, Molstad S. Medical audit changes physicians' prescribing of antibiotics for respiratory tract infections. Scandinavian Journal of Primary Health Care. 1999;17(3):180. [pmid: 10555249].
107 Mainous AG 3rd, Hueston WJ, Love MM, Evans ME, Finger R. An evaluation of statewide strategies to reduce antibiotic overuse. Family Medicine. 2000;32(1):22. [pmid: 10645510].
108 Hickman DE, Stebbins MR, Hanak JR, Guglielmo BJ. Pharmacy-based intervention to reduce antibiotic use for acute bronchitis. Annals of Pharmacotherapy. 2003;37(2):187. [pmid: 12549944].
109 Hennessy TW, Petersen KL, Bruden D, et al. Changes in Antibiotic-Prescribing Practices and Carriage of Penicillin-Resistant Streptococcus pneumoniae: A Controlled Intervention Trial in Rural Alaska. Clin Infect Dis. 2002;34:1543-1550. [pmid: 12032887].
110 Gonzalez Ochoa E, Armas Perez L, Bravo Gonzalez JR, Cabrales Escobar J, Rosales Corrales R, Abreu Suarez G. Prescription of antibiotics for mild acute respiratory infections in children. Bulletin of the Pan American Health Organization. 1996;30(2):106. [pmid: 8704751].
111 Gonzales R, Steiner JF, Lum A, Barrett PHJ. Decreasing antibiotic use in ambulatory practice: impact of a multidimensional intervention on the treatment of uncomplicated acute bronchitis in adults. JAMA. 1999;281(16):1512-1519. [pmid: 10227321].
112 Coenen S, Van Royen P, Michiels B, Denekens J. Optimizing antibiotic prescribing for acute cough in general practice: a cluster-randomized controlled trial. J Antimicrob Chemother. 2004;54(3):661-672. [pmid: 15282232].
113 Belongia EA, Sullivan BJ, Chyou PH, Madagame E, Reed KD, Schwartz B. A community intervention trial to promote judicious antibiotic use and reduce penicillin-resistant Streptococcus pneumoniae carriage in children. Pediatrics. 2001;108(3):575. [pmid: 11533321].
114 Zwar N, Wolk J, Gordon J, Sanson-Fisher R, Kehoe L. Influencing antibiotic prescribing in general practice: A trial of prescriber feedback and management guidelines. Family Practice. 1999;16(5):495. [pmid: 10533946].
115 Angunawela I, Diwan VK, Tomson G. Experimental evaluation of the effects of drug information on antibiotic prescribing: a study in outpatient care in an area of Sri lanka. International Journal of Epidemiology. 1991;20(2):558. [pmid: 1917265].
116 Bexell A, Lwando E, von Hofsten B, Tembo S, Eriksson B, Diwan VK. Improving drug use through continuing education: a randomized controlled trial in Zambia. Journal of Clinical Epidemiology. 1996;49:355. [pmid: 8676185].
117 Gutierrez G, Guiscafre H, Bronfman M, Walsh J, Martinez H, Munoz O. Changing physician prescribing patterns: evaluation of an educational strategy for acute diarrhea in Mexico City. Medical Care. 1994;32(5):436. [pmid: 8182972].
118 McIsaac WJ, Goel V. Effect of an explicit decision-support tool on decisions to prescribe antibiotics for sore throat. Medical Decision Making. 1998;18(2):220. [pmid: 9566455].
119 McIsaac WJ, Goel V, To T, Permaul JA, Low DE. Effect on antibiotic prescribing of repeated clinical prompts to use a sore throat score: lessons from a failed community intervention study. Journal of Family Practice. 2002;51(4):339. [pmid: 11978257].
120 Foxman B, Valdez RB, Lohr KN, Goldberg GA, Newhouse JP, Brook RH. The effect of cost sharing on the use of antibiotics in ambulatory care: results from a population-based randomized controlled trial. Journal of Chronic Diseases. 1987;40(5):429. [pmid: 3104386].
121 McNulty CA, Kane A, Foy CJ, Sykes J, Saunders P, Cartwright KA. Primary care workshops can reduce and rationalize antibiotic prescribing. Journal of Antimicrobial Chemotherapy. 2000;46(3):493. [pmid: 10980182].
122 Perz JF, Craig AS, Coffey CS, et al. Changes in antibiotic prescribing for children after a community-wide campaign. JAMA. 2002;287(23):3103. [pmid: 12069673].
123 Christakis DA, Zimmerman FJ, Wright JA, Garrison MM, Rivara FP, Davis RL. A randomized controlled trial of point-of-care evidence to improve the antibiotic prescribing practices for otitis media in children. Pediatrics. 2001;107(2).
124 McConnell TS, Cushing AH, Bankhurst AD, Healy JL, McIlvenna PA, Skipper BJ. Physician behavior modification using claims data: tetracycline for upper respiratory infection. West J Med. 1982;137(5):448-450. [pmid: 6891147]. [pmcid: 1274191].
125 O'Connell DL, Henry D, Tomlins R. Randomised controlled trial of effect of feedback on general practitioners' prescribing in Australia. BMJ. 1999;318(7182):507-511. [pmid: 10024260]. [pmcid: 27749].
126 Finkelstein JA, Davis RL, Dowell SF, et al. Reducing antibiotic use in children: a randomized trial in 12 practices. Pediatr. 2001;108:1-7.
127 Cates C. An evidence based approach to reducing antibiotic use in children with acute otitis media: controlled before and after study. Bmj. 1999;318(7185):715-716. [pmid: 10074019]. [pmcid: 27785].
128 Wilson EJ, Nasrin D, Dear KB, Douglas RM. Changing GPs' antibiotic prescribing: a randomised controlled trial. Commun Dis Intell. 2003;27(Suppl):S32-38. [pmid: 12807271].
129 Little P, Gould C, Williamson I, Moore M, Warner G, Dunleavey J. Pragmatic randomised controlled trial of two prescribing strategies for childhood acute otitis media. BMJ. 2001;322(7282):336-342. [pmid: 11159657]. [pmcid: 26576].
130 Arroll B, Kenealy T, Kerse N. Do Delayed Prescriptions Reduce the Use of Antibiotics for the Common Cold?. J Fam Pract. 2002;51(4):324-328. [pmid: 11978254].
131 Dowell J, Pitkethly M, Bain J, Martin S. A randomised controlled trial of delayed antibiotic prescribing as a strategy for managing uncomplicated respiratory tract infection in primary care. Br J Gen Pract. 2001;51(3):200-205. [pmid: 11255901]. [pmcid: 1313951].
132 Pshetizky Y, Naimer S, Shvartzman P. Acute otitis media—a brief explanation to parents and antibiotic use. Fam Pract. 2003;20(4):417-419. [pmid: 12876113].
133 Macfarlane J, Holmes W, Gard P, et al. Reducing antibiotic use for acute bronchitis in primary care: blinded, randomised controlled trial of patient information leaflet * Commentary: More self reliance in patients and fewer antibiotics: still room for improvement. BMJ. 2002;324(7329):91. [pmid: 11786454].
134 Hulscher ME, Laurant MG, Grol RP. Process evaluation on quality improvement interventions. Qual Saf Health Care. 2003;12(1):40-46. [pmid: 12571344]. [pmcid: 1743654].
135 Avorn J, Soumerai SB. Improving drug-therapy decisions through educational outreach. A randomized controlled trial of academically based “detailing”. New England Journal of Medicine. 1983;308(24):1457-1463. [pmid: 6406886].
136 Braybrook S, Walker R. Influencing prescribing in primary care: a comparison of two different prescribing feedback methods. Journal of Clinical Pharmacy & Therapeutics. 1996;21(4):247. [pmid: 8933299].
137 Bush PJ, Rabin DL, Spector KK. Evaluation of a drug therapy protocol in an HMO. Medical Care. 1979;17(6):566. [pmid: 449432].
138 De Santis G, Harvey KJ, Howard D, Mashford ML, Moulds RF. Improving the quality of antibiotic prescription patterns in general practice. The role of educational intervention. Medical Journal of Australia. 1994;160(8):502. [pmid: 8170427].
139 Dolovich L, Levine M, Tarajos R, Duku E. Promoting optimal antibiotic therapy for otitis media using commercially sponsored evidence-based detailing: A prospective controlled trial. Drug Information Journal. 1999;33(4):1067.
140 Farris KB, Kirking DM, Shimp LA, Opdycke RA. Design and results of a group counter-detailing DUR educational program. Pharmaceutical Research. 1996;13(10):1445. [pmid: 8899833].
141 Friis H, Bro F, Mabeck CE, Vejlsgaard R. Changes in prescription of antibiotics in general practice in relation to different strategies for drug information. Danish Medical Bulletin. 1991;38(4):380. [pmid: 1914537].
142 Harrison A, Karim SA, Floyd K, et al. Syndrome packets and health worker training improve sexually transmitted disease case management in rural South Africa: randomized controlled trial. AIDS. 2000;14(17):2769. [pmid: 11125896].
143 Hux JE, Melady MP, DeBoer D. Confidential prescriber feedback and education to improve antibiotic use in primary care: a controlled trial. CMAJ. 1999;161(4):388. [pmid: 10478162]. [pmcid: 1230539].
144 Ilett KF, Johnson S, Greenhill G, et al. Modification of general practitioner prescribing of antibiotics by use of a therapeutics adviser (academic detailer). British Journal of Clinical Pharmacology. 2000;49(2):168. [pmid: 10671912]. [pmcid: 2014897].
145 Klein LE, Charache P, Johannes RS. Effect of physician tutorials on prescribing patterns of graduate physicians. Journal of Medical Education. 1981;56(6):504. [pmid: 7346637].
146 Lagerlov P, Loeb M, Andrew M, Hjortdahl P. Improving doctors' prescribing behaviour through reflection on guidelines and prescription feedback: a randomised controlled study. Quality in Health Care. 2000;9(3):159. [pmid: 10980076]. [pmcid: 1743532].
147 Lundborg CS, Wahlstrom R, Oke T, Tomson G, Diwan VK. Influencing prescribing for urinary tract infection and asthma in primary care in Sweden: a randomized controlled trial of an interactive educational intervention. Journal of Clinical Epidemiology. 1999;52(8):801. [pmid: 10465325].
148 MacCara ME, Sketris IS, Comeau DG, Weerasinghe SD. Impact of a limited fluoroquinolone reimbursement policy on antimicrobial prescription claims. Annals of Pharmacotherapy. 2001;35(78):852. [pmid: 11485132].
149 Peterson GM, Stanton LA, Bergin JK, Chapman GA. Improving the prescribing of antibiotics for urinary tract infection. Journal of Clinical Pharmacy & Therapeutics. 1997;22(2):147. [pmid: 9373814].
150 Raz R, Porat V, Ephros M. Can an educational program improve the diagnosis and treatment of pharyngotonsillitis in the ambulatory care setting?. Israel Journal of Medical Sciences. 1995;31(7):432. [pmid: 7607871].
151 Rokstad K, Straand J, Fugelli P. Can drug treatment be improved by feedback on prescribing profiles combined with therapeutic recommendations? A prospective, controlled trial in general practice. Journal of Clinical Epidemiology. 1995;48(8):1061-1068. [pmid: 7775993].
152 Schaffner W, Ray WA, Federspiel CF, Miller WO. Improving antibiotic prescribing in office practice. A controlled trial of three educational methods. JAMA. 1983;250(13):1728. [pmid: 6350633].
153 Sondergaard J, Andersen M, Stovring H, Kragstrup J. Mailed prescriber feedback in addition to a clinical guideline has no impact: a randomised, controlled trial. Scandinavian Journal of Primary Health Care. 2003;21(1):47. [pmid: 12718461].
154 Veninga CC, Denig P, Zwaagstra R, Haaijer-Ruskamp FM. Improving drug treatment in general practice. Journal of Clinical Epidemiology. 2000;53(7):762. [pmid: 10941955].
155 Flottorp S, Havelsrud K, Oxman AD. Process evaluation of a cluster randomized trial of tailored interventions to implement guidelines in primary care—why is it so hard to change practice?. Family Practice. 2003;20(3):333. [pmid: 12738704].
156 Dickersin K. The existence of publication bias and risk factors for its occurrence. Jama. 1990;263(10):1385-1389. [pmid: 2406472].
157 Mangione-Smith R, Elliott MN, McDonald L, McGlynn EA. An observational study of antibiotic prescribing behavior and the Hawthorne effect. Health Serv Res. 2002;37(6):1603-1623. [pmid: 12546288]. [pmcid: 1464047].
158 Hueston WJ, Slott K. Improving quality or shifting diagnoses? What happens when antibiotic prescribing is reduced for acute bronchitis?. Archives of Family Medicine. 2000;9(9):933. [pmid: 11031404].
159 Harris RH, MacKenzie TD, Leeman-Castillo B, et al. Optimizing antibiotic prescribing for acute respiratory tract infections in an urban urgent care clinic. J Gen Intern Med. 2003;18(5):326-334. [pmid: 12795730]. [pmcid: 1494862].
160 Tunis SR, Stryer DB, Clancy CM. Practical clinical trials: increasing the value of clinical research for decision making in clinical and health policy. Jama. 2003;290(12):1624-1632. [pmid: 14506122].