# Acknowledgments

We are grateful to our many technical experts and content reviewers for their uniformly thoughtful comments.

We give special thanks to our panel of technical advisors: Jeremy Grimshaw, MBChB, PhD, University of Ottawa, Cochrane Collaboration Effective Practice and Organisation of Care Group (EPOC); Andrew Oxman, MD, MSc, Department of Health Services Research, Norwegian Directorate for Health and Social Welfare, EPOC; Russell Glasgow, PhD, Kaiser Permanente, Colorado; Martin Eccles, MD, Centre for Health Services Research, University of Newcastle upon Tyne, EPOC; Harmon Jordan, ScD, previously with the New England Medical Center Evidence-based Practice Center and currently at Abt Associates; Val Lawrence, MD, MSc, The University of Texas Health Science Center at San Antonio and South Texas Veterans Health Care System; James Zazzali, PhD, RAND Institute; and Charles Homer, MD, MPH, National Institute for Children's Health Care Quality; whose attentive guidance to the entire Closing the Quality Gap series and continued assistance on this report was critical to the project.

We are grateful to our panel of peer reviewers: Richard Besser, MD, Centers for Disease Control and Prevention; Edward Belongia, MD, Marshfield Clinic; Jonathon Finkelstein, MD, MPH, Department of Ambulatory Care and Prevention, Harvard Medical School; Kitty Corbett, PhD, Denver University; Randall Stafford, MD, PhD, Stanford University; Brian Strom, MD, MPH, CERT Program, University of Pennsylvania; and Theoklis Zaoutis, MD, Department of Pediatrics, University of Pennsylvania School of Medicine; who read early drafts of the chapters and provided timely and detailed comments.

We also extend our thanks to David Atkins, MD, MPH, Marian James, PhD, MA, and Susan Norris, MD, MPH, from the Agency for Healthcare Research and Quality for their assistance with this report.