# Results

Our search strategy ( Figure 4 ) yielded a total of 521 citations (509 from the EPOC database and 12 additional studies identified from MEDLINE®). Of these, we excluded 374 after title and abstract review, the majority of which (N=222) were outside our scope due to a focus on inpatient antimicrobial use, antimicrobial use in chronic diseases, or prescribing of medications other than antimicrobials. We reviewed the full text of the remaining 147 articles. Many of these (N=35) were excluded due to ineligible study design (e.g., single-group or before-after studies). Other reasons for exclusion included lack of eligible study outcomes (N=9), inappropriate focus (N=13), and unavailable full-text article (N=5 ^7^ ). Our final sample included 54 articles, six of which reported the effects of an intervention on both the antibiotic [underlined: treatment] decision and the antibiotic [underlined: selection] decision ( Tables 1A and 1B ).

7 These included three studies published only as abstracts on the International Network for Rational Use of Drugs Web site ( www.inrud.org ) and two studies for which the journal could not be located.

Figure 4. Search strategy and article triage

Figure 4 Legend

Reasons for Exclusion

R1 = Not an evaluation of an intervention

R2 = Not a QI strategy

R3 = Ineligible topic (focused on inpatient care, antimicrobial use in chronic disease, not related to antimicrobial use)

R4 = Ineligible study design

R5 = No eligible outcomes

R6 = Foreign language article

R7 = Other (outcomes data not available for entire population studied, e.g., only presented in subgroups, article not available, duplicate article)

** Research question 1: Which quality improvement strategies reduce prescribing of antibiotics for nonbacterial illnesses?

** Research question 2: Which quality improvement strategies improve selection of the appropriate antibiotic for treatment of bacterial illnesses?

The core investigators (who were responsible for full-text article abstraction and data analysis) were SRR, MAS, and RG

Table 1A QI strategies and outcomes for antibiotic treatment studies

Author | Setting and Target | Patient Population | Disease Target | Study Design (Effective sample size) | Study Period (Duration/months) | QI Strategies Employed | | | | | | | | Outcomes Reported
| | | | | | Pt Ed | Delayed | Clin Ed | Clin Remind | Audit & Fdbck | Org Change | Pt Incentives | Clin Incentives
Finkelstein J ^1^ | United States | Children | ARI | RCT (—) | 1997-1998 (12) | ✓ | | ✓ | | ✓ | | | | Antibiotics prescribed per person-year
| 12 practices affiliated with 2 managed care organizations
Angunawela I ^2^ | Sri Lanka | All patients | Not specified | RCT (1048) | 1988 (2) | | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| General practitioners at rural primary care clinics
Angunawela I ^3^ | Sri Lanka | All patients | Not specified | RCT (1348) | 1988 (2) | | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| General practitioners at rural primary care clinics
Arroll, B ^4^ | New Zealand | All patients | ARI (Common cold) | RCT (129) | — (10 days) | | ✓ | | | | | | | % of pt visits resulting in ABX prescription
| General practitioners | | | | | | | | | | | | | Clinical outcomes
| | | | | | | | | | | | | | Pt/Clin Satisfaction
Belongia, E ^5^ | United States | Children | ARI (Common cold, Acute sinusitis, Pharyngitis, Bronchitis, Otitis media) | CBA (370) | 1997 (4) | ✓ | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| Multiple counties in Northern Wisconsin | | | | | | | | | | | | | Antimicrobial resistance
Bexell, A ^6^ | Zambia | All patients | Not specified | QRCT (1113) | 1991 (5) | | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| General Practices
Christakis, D ^7^ | United States | Children | ARI (Otitis media) | RCT (—) | — (8) | | | | ✓ | | | | | Change in % of pt visits resulting in ABX prescription
| Academic pediatric primary care clinic | | | | | | | | | | | | | Duration of ABX therapy
Dowell, J ^8^ | UK | Adults | ARI (Cough) | RCT (194) | 1997-1998 (—) | | ✓ | | | | | | | % of pt visits resulting in ABX prescription
| General practitioners in Scotland | | | | | | | | | | | | | Clinical outcome
| | | | | | | | | | | | | | Health services utilization
| | | | | | | | | | | | | | Pt/Clin Satisfaction
Flottorp, S ^9^ | Norway | All patients | ARI (Sore throat) | RCT (1739) | 2000-2001 (9) | ✓ | | ✓ | ✓ | | ✓ | ✓ | ✓ | % of pt visits resulting in ABX prescription
| 142 General practices | | | | | | | | | | | | | Health services utilization
Foxman, B ^10^ | United States | All patients | Not specified | RCT (—) | 1975 (12) | | | | | | | ✓ | | ABX prescriptions per person-year
| 6 cities: Dayton, OH; Seattle, WA; Fitchburg, MA; Franklin County, MA; Charleston, SC; Georgetown County, SC
Gonzales, R ^11^ | United States | Adults | ARI (Acute bronchitis) | CBA (1213) | 1997-1998 (4) | ✓ | | ✓ | | ✓ | | | | % of pt visits resulting in ABX prescription
| 4 HMO primary care practices | | | | | | | | | | | | | Health services utilization
Gonzales, R ^12^ | United States | Adults | ARI (Acute bronchitis) | CBA (1197) | 1997-1998 (4) | ✓ | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| 4 HMO primary care practices | | | | | | | | | | | | | Health services utilization
Gonzales-Ochoa, E ^13^ | Cuba | Children | ARI | QRCT (122) | 1991 (12) | ✓ | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| General practitioners in 4 areas of Havana
Gonzales-Ochoa, E ^14^ | Cuba | Children | ARI | QRCT (100) | 1991 (12) | | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| General practitioners in 4 areas of Havana
Gonzales-Ochoa, E ^15^ | Cuba | Children | ARI | QRCT (100) | 1991 (12) | ✓ | | | | | | | | % of pt visits resulting in ABX prescription
| General practitioners in 4 areas of Havana
Gutierrez, G ^16^ | Mexico | All patients | Diarrhea | CBA (152) | — (18) | | | ✓ | | ✓ | | | | % of pt visits resulting in ABX prescription
| General practitioners at health care clinics of the Mexican Social Security Institute
Hennessy, T ^17^ | United States | All patients | ARI | CBA (2163) | 1998-1999 (6) | ✓ | | ✓ | | | | | | % of pt visits resulting in ABX prescription Antimicrobial resistance
| 13 rural Alaskan villages
Hickman, D ^18^ | United States | All patients | ARI (Acute bronchitis) | CBA (1943) | 1998 (4) | ✓ | | ✓ | | ✓ | | | | % of pt visits resulting in ABX prescription
| Suburban community-based physician group | | | | | | | | | | | | | Health services utilization
Little, P ^19^ | UK | Children | ARI (Otitis media) | RCT (285) | — (1 week) | | ✓ | | | | | | | % of pt visits resulting in ABX prescription
| General practices in southwest England | | | | | | | | | | | | | Clinical outcome
| | | | | | | | | | | | | | Pt/Clin Satisfaction
Macfarlane, J ^20^ | UK | Adults | ARI (Acute bronchitis) | RCT (205) | 1999-2000 (11) | ✓ | ✓ | | | | | | | % of pt visits resulting in ABX prescription
| General practices | | | | | | | | | | | | | Health service utilization
Mainous, A ^21^ | United States | Children | ARI | RCT (2564) | 1997 (1) | ✓ | | | | | | | | % of pt visits resulting in ABX prescription
| 8 Medicaid administrative regions in Kentucky
Mainous, A ^22^ | United States | Children | ARI | RCT (2740) | 1997 (1) | | | | | ✓ | | | | % of pt visits resulting in ABX prescription
| 8 Medicaid administrative regions in Kentucky
Mainous, A ^23^ | United States | Children | ARI | RCT (2297) | 1997 (1) | ✓ | | | | ✓ | | | | % of pt visits resulting in ABX prescription
| 8 Medicaid administrative regions in Kentucky
McConnell, T ^24^ | United States | All patients | ARI | RCT (—) | 1997-1998 (?) | | | ✓ | | ✓ | | | | ABX prescriptions per provider
| New Mexico Medicaid program | | | | | | | | | | | | | Compliance to clinical guideline
McIsaac, W ^25^ | Canada | All patients | ARI (Sore throat) | RCT (396) | 1996 (—) | | | | ✓ | | | | | % of pt visits resulting in ABX prescription
| Family physicians in Ontario
McIsaac, W ^26^ | Canada | All patients | ARI (Sore throat) | RCT (99) | 1998 (—) | | | | ✓ | | | | | % of pt visits resulting in ABX prescription
| Family physicians in Ontario
Melander, E ^27^ | Sweden | All patients | ARI | CBA (857) | 1995 (—) | | | ✓ | | ✓ | | | | % of pt visits resulting in ABX prescription
| General practitioners
Meyer, J ^28^ | South Africa | All patients | ARI Diarrhea | RCT (383) | 1997 (6) | | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| Nurses in primary health clinics
O'Connell, D ^29^ | Australia | All patients | Not specified | RCT (—) | 1995 (7) | | | ✓ | | ✓ | | | | ABX prescriptions per 100 patient visits
| General practitioners in rural area
Perz, J ^30^ | United States | Children | Not specified | CBA (—) | 1997-1998 (12) | ✓ | | ✓ | | | | | | ABX prescriptions per person- year
| 4 counties in Tennessee
Santoso, B ^31^ | Indonesia | Children | Diarrhea | RCT (1638) | — | | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| General practitioners in Yogyakarta and Java provinces
Santoso, B ^32^ | Indonesia | Children | Diarrhea | RCT (1638) | — | | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| General practitioners in Yogyakarta and Java provinces
Zwar, N ^33^ | Australia | All patients | ARI | RCT (—) | — | | | ✓ | | ✓ | | | | % of pt visits resulting in ABX prescription
| General practitioner trainees in New South Wales
McNulty, C ^34^ | UK | All patients | Not specified | CBA (—) | 1997 (7 weeks) | | | ✓ | | ✓ | | | | Total ABX prescriptions
| General practices in Gloucestershire | | | | | | | | | | | | | Cost
Welschen, I ^35^ | The Netherlands | All patients | ARI | QRCT (1074) | 2000-2001 (9) | ✓ | | ✓ | | ✓ | | | | % of pt visits resulting in ABX prescription
| General practitioners in Utrecht | | | | | | | | | | | | | Pt/Clin Satisfaction
Molstad, S ^36^ | Sweden | All patients | ARI (Rhinitis, Pharyngitis, Acute bronchitis) | CBA (372) | 1985 (2) | | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| General practitioners at community health centers
Cates, C ^37^ | UK | Children | ARI (Otitis media) | CBA (—) | 1997-1998 (12) | ✓ | ✓ | | | | | | | ABX prescriptions per clinic
| General practitioners in outpatient clinics in Hertfordshire
Pshetizky, Y ^38^ | Israel | Children | ARI (Otitis media) | RCT (81) | 1998-1999 | ✓ | ✓ | | | | | | | % of pt visits resulting in ABX prescription
| General practitioners
Smabrekke, L ^39^ | Norway | Children | ARI (Otitis media) | CBA (329) | 1998-1999 (4) | ✓ | | ✓ | | | | | | % of pt visits resulting in ABX prescription
| Physicians and nurses at urgent care clinic
Wilson, E ^40^ | Australia | Children | ARI | RCT (—) | 1998 (4) | ✓ | ✓ | ✓ | | | | | | Prescriptions per 100 patient visits
| General practitioners in Canberra
Coenen, S ^41^ | Belgium | Adults | ARI | RCT (238) | 2001 (1) | | | ✓ | | | | | ✓ | % of pt visits resulting in ABX prescription
| General practitioners | | | | | | | | | | | | | Cost
| | | | | | | | | | | | | | Health service utilization
| | | | | | | | | | | | | | Clinical outcomes

Abbreviations: ARI = acute respiratory infection; UTI = urinary tract infection; ABX = antibiotics, CBA = controlled before-after study; RCT = randomized controlled trial; QRCT = quasi randomized controlled trial; Pt Ed = patient education; Delayed = provision of delayed prescriptions; Clin Remind = Clinician Reminder; Clin Ed = clinician education; Audit & Fdbck = clinician audit and feedback; Org Change = Organizational change; Pt Incentives = patient-directed financial or regulatory incentives; Clin Incentives = clinician-directed financial or regulatory incentives

Table 1B QI strategies and outcomes for antibiotic selection studies

Author | Setting | Patient Population Target | Disease Target | Study Design (Sample Size) | Study Period (Duration/months) | QI Strategies Employed | | | | | | | | Outcomes Reported
| | | | | | Pt Ed | Delayed | Clin Ed | Clin Remind | Audit & Fdbck | Org Change | Pt Incentives | Clin Incentives
Avorn, J ^42^ | United States | Medicaid patients | Not specified | RCT (—) | 1980-1981 (6) | | | ✓ | | | | | | % change in prescribing of contraindicated ABX
| Physicians in 4 state Medicaid programs (Arkansas, New Hampshire, Vermont, and the District of Columbia)
Avorn, J ^43^ | United States | Medicaid patients | Not specified | RCT (—) | 1980-1981 (6) | | | ✓ | | | | | | % change in prescribing of contraindicated ABX
| Physicians in 4 state Medicaid programs (Arkansas, New Hampshire, Vermont, and the District of Columbia)
Braybrook, S ^44^ | UK | All patients | UTI | CBA (—) | 1992-1993 (6) | | | ✓ | | ✓ | | | ✓ | % change in prescribing of contraindicated ABX
| 66 family health practices in Wales
Braybrook, S ^45^ | UK | All patients | UTI | CBA (—) | 1992-1993 (6) | | | ✓ | | ✓ | | | ✓ | % change in prescribing of contraindicated ABX
| 66 family health practices in Wales
Bush, P ^46^ | United States | Children enrolled in HMO | ARI (Otitis Media) | CBA (348) | 1975-1976 (—) | | | ✓ | | | | | | Compliance to clinical guideline
| Pediatricians at 3 HMO sites in Washington, DC
Bush, P ^47^ | United States | Children enrolled in HMO | ARI (Otitis Media) | CBA (247) | 1975-1976 (—) | | | ✓ | | | | | | Compliance to clinical guideline
| Pediatricians at 3 HMO sites in Washington, DC
De Santis, G ^48^ | Australia | All patients | ARI (Tonsillitis) | RCT (788) | — (3) | | | ✓ | | | | | | Compliance to clinical guideline
| General practitioners in 8 rural and metropolitan Victorian Health Department regions
Dolovich, L ^49^ | Canada | Children | ARI (Otitis Media) | RCT (—) | — | | | ✓ | | | | | | % change in market share of recommended ABX
| Family physicians in Southern Ontario
Farris, KB ^50^ | United States | HMO patients | ARI (Otitis media, Sinusitis, Bronchitis, Community acquired pneumonia) | CBA (—) | 1991-1992 (—) | | | ✓ | | ✓ | | | | % prescribed recommended drugs
| Family physicians in HMO in southeastern Michigan | | | | | | | | | | | | | Cost
| | | | | | | | | | | | | | Pt/Clin Satisfaction
Friis, H ^51^ | Denmark | All patients | ARI | CBA (2600) | — (3) | | | ✓ | | | | | | % prescribed recommended drugs
| General practitioners in 5 counties
Friis, H ^52^ | Denmark | All patients | ARI | CBA (2046) | — (3) | | | ✓ | | | | | | % prescribed recommended drugs
| General practitioners in 5 counties)
Hux, J ^53^ | Canada | Adults | ARI UTI | RCT (—) | 1996-1997 (6) | | | ✓ | | ✓ | | | | Compliance to clinical guideline
| Family physicians in Ontario | | | | | | | | | | | | | Cost
Ilett, K ^54^ | Australia | All patients | ARI UTI | RCT (2368) | 1997 (2) | | | ✓ | | | | | | % prescribed recommended drugs
| General practitioners in the Perth metropolitan area | | | | | | | | | | | | | Cost
Klein, L ^55^ | United States | Adults | UTI | CBA (44) | 1978-1979 (—) | | | ✓ | | | | | | Compliance to clinical guideline
| Residents in academic emergency room and primary care center
Lagerlov, P ^56^ | Norway | Adults | UTI | RCT (—) | 1995 (—) | | | ✓ | | ✓ | | | | Duration of ABX therapy
| General practitioners
Lundborg, C ^57^ | Sweden | Adult women | UTI | RCT (1734) | 1995 (6) | | | ✓ | | ✓ | | | | Compliance to clinical guideline
| 36 General practitioner groups | | | | | | | | | | | | | Duration of ABX therapy
MacCara, M ^58^ | Canada | Adults | Not specified | ITS (—) | 1997 (12) | | | | | | | ✓ | ✓ | Change in number of prescriptions for contraindicated ABX
| General practitioners
McNulty, C ^59^ | UK | All patients | ARI UTI | CBA (121,857) | 1997 (7) | | | ✓ | | ✓ | | | | % prescribed recommended drugs
| 84 general practices in Gloucestershire | | | | | | | | | | | | | Cost
Peterson, G ^60^ | Australia | Adults | UTI | CBA (26,968) | 1995 (5) | | | ✓ | | | | | | % prescribed recommended drugs
| General practitioners in Southern Tasmania
Raz, R ^61^ | Israel | All patients | ARI (Pharyngitis) | CBA (3841) | 1988 (1) | | | ✓ | | | | | | % prescribed recommended drugs
| Physicians and nurses at 3 community outpatient clinics
Rokstad, K ^62^ | Norway | Adults | UTI | CBA (210) | 1989 (—) | | | | | ✓ | | | | % prescribed recommended drugs
| General practitioners in 2 counties | | | | | | | | | | | | | Duration of ABX therapy
Schaffner, W ^63^ | United States | Medicaid patients | Not specified | CBA (—) | 1980-1981 (16) | | | ✓ | | | | | | % change in prescriptions for contraindicated ABX
| Physicians participating in Tennessee Medicaid program
Schaffner, W ^64^ | United States | Medicaid patients | Not specified | CBA (—) | 1980-1981 (16) | | | ✓ | | | | | | % change in prescriptions for contraindicated ABX
| Physicians participating in Tennessee Medicaid program
Schaffner, W ^65^ | United States | Medicaid patients | Not specified | CBA (—) | 1980-1981 (16) | | | ✓ | | | | | | % change in prescriptions for contraindicated ABX
| Physicians participating in Tennessee Medicaid program
Schaffner, W ^66^ | United States | Medicaid patients | Not specified | CBA (—) | 1980-1981 (16) | | | ✓ | | | | | | % change in prescriptions for contraindicated ABX
| Physicians participating in Tennessee Medicaid program
Sondergaard, J ^67^ | Denmark | All patients | ARI | RCT (6763) | 1988-1989 (4) | | | ✓ | | ✓ | | | | % prescribed recommended drugs
| 181 general practices
Veninga, C ^68^ | Netherlands | Adult women | UTI | RCT (3433) | 1996 (5) | | | ✓ | | ✓ | | | | Duration of ABX therapy
| General practitioners | | | | | | | | | | | | | Compliance to clinical guideline
Melander, E ^69^ | Sweden | All patients | ARI | CBA (68) | 1995 (—) | | | ✓ | | ✓ | | | | % prescribed recommended drugs
| General practices in 3 communities
Harrison, A ^70^ | South Africa | Adults | STD | RCT (77) | 1996-1997 (15) | ✓ | | ✓ | | | | | | Compliance to clinical guideline
| Practitioners in 10 primary care clinics in rural KwaZulu - Natal)
Zwar, N ^71^ | Australia | All patients | ARI (tonsillitis, pharyngitis) | RCT (—) | — | | | ✓ | | ✓ | | | | Compliance to clinical guideline
| General practitioner trainees in New South Whales
Molstad, S ^72^ | Sweden | All patients | ARI (Rhinitis, pharyngitis, acute bronchitis) | CBA (209) | 1985 (2) | | | ✓ | | | | | | % prescribed recommended drugs
| General practitioners at 3 community health centers
Smabrekke, L ^73^ | Norway | Children | ARI (Otitis media) | CBA (260) | 1998-1999 (4) | ✓ | | ✓ | | | | | | % prescribed recommended drugs
| Physicians at an acute care center
Coenen, S ^74^ | Belgium | All patients | ARI (Acute cough) | RCT (67) | 2001 (1) | | | ✓ | | | | | ✓ | Compliance to clinical guideline
| General practitioners

Abbreviations: ARI = acute respiratory infection; UTI = urinary tract infection; ABX = antibiotics, CBA = controlled before-after study; RCT = randomized controlled trial; ITS = interrupted time series; Pt Ed = patient education; Delayed = provision of delayed prescriptions; Clin Ed = clinician education; Clin Remind = clinician reminder; Audit & Fdbck = clinician audit and feedback; Org Change = organizational change; Pt Incentives = patient-directed financial or regulatory incentives; Clin Incentives = clinician-directed financial or regulatory incentive

## Studies To Improve the Antibiotic Treatment Decision

### Studies Meeting Inclusion Criteria

Our final sample included 34 studies reporting a total of 41 trials (i.e., 41 separate comparisons against comparison groups). Of these, 24 trials (from 17 studies ^87,^ ^101^ – ^116^ ) reported data as the percentage of visits where an antimicrobial was prescribed before and after the intervention, and thus were suitable for median effect size analysis. Three other studies ^117^ – ^119^ reported this outcome but did not report complete pre- and post-intervention data; these were excluded from median effects analyses and instead were summarized qualitatively.

The other trials included nine studies ^120^ – ^128^ that reported a variety of continuous outcomes, such as antibiotic prescriptions per person-year ^120,^ ^122,^ ^123^ or antibiotic prescriptions per provider ^121,^ ^123^ – ^125^ ; these studies were analyzed separately in a qualitative fashion. Five studies of delayed prescribing ^129^ – ^133^ were also analyzed separately, as pre-intervention prescribing data were not provided.

### Settings, Goals, and Target Population of Studies

Appendix B * contains summaries of each included study. These tables organize studies by the setting and patient population in which the outcome was measured. We chose to group studies by the measured population, rather than the targeted population, in order to help stakeholders identify the studies whose results are most applicable to their settings. These tables also contain the QI strategies used, and specific details of the interventions themselves, as well as the individual study results.

* Appendixes cited in this report are provided electronically at http://www.ahrq.gov/downloads/pub/evidence/pdf/medigap/medigap.pdf

Nearly all of the studies took place in outpatient primary care clinics (N=32), with two conducted in an urgent care or walk-in clinic. ^102,^ ^108^ Most studies took place outside the US (N=24), including 11 from Europe, ^87,^ ^101,^ ^102,^ ^104,^ ^106,^ ^112,^ ^114,^ ^127,^ ^129,^ ^130,^ ^133^ three from Australia, ^114,^ ^125,^ ^128^ two from Canada, ^118,^ ^119^ two from Africa, ^105,^ ^116^ and the remainder from other countries. Of the 28 trials which reported the period during which the study was conducted, 22 took place in the last decade. ^87,^ ^101,^ ^102,^ ^105^ – ^109,^ ^111^ – ^113,^ ^118,^ ^119,^ ^121,^ ^122,^ ^125^ – ^128,^ ^131^ – ^133^

Most included studies sought to reduce the prescribing of antibiotics for targeted conditions in which antibiotics are generally not recommended ( Table 1C ). Six studies did not identify a specific target condition, instead focusing on reducing overall antibiotic prescribing in a broader population. ^115,^ ^116,^ ^120^ – ^122,^ ^125^ Among the 28 studies with a specific disease focus, nearly all (N=26) addressed antibiotic prescribing for acute respiratory infections; two other studies ^103,^ ^117^ addressed prescribing for acute diarrhea. Antibiotic prescribing for children was targeted in 13 studies ^102,^ ^110,^ ^113,^ ^115,^ ^117,^ ^119,^ ^122,^ ^123,^ ^126^ – ^129,^ ^132^ ; however, no studies specifically addressed prescribing for elderly patients or patients of lower socioeconomic status. Five studies ^107,^ ^111,^ ^117,^ ^122,^ ^126^ selected patients with a specific type of insurance (e.g., managed care or Medicaid enrollees). The median baseline prescribing rate was 31.0% in interventions targeting general ARIs (N=9 studies supplying data, IQR 21.4% to 37.0%), but, among interventions targeting a specific ARI (N=5 studies supplying data), prescribing rate ranged as high as 78% in a study examining acute bronchitis ^111^ and 95% in a study examining pediatric otitis media. ^102^

Table 1C Antibiotic treatment studies: target condition and population

| Studies targeting children | | Studies targeting adults | | Studies targeting entire population | | Total
| Specific insurance | No specific insurance | Specific insurance | No specific insurance | Specific insurance | No specific insurance
General ARI | 2 [ ^1^ , ^21^ ] | 5 [ ^5^ , ^7^ , ^13^ , ^26^ , ^40^ ] | 0 | 1 [ ^8^ ] | 0 | 7 [ ^18^ , ^24^ , ^27^ , ^28,^ ^33^ , ^35^ , ^36^ ] | 15
Specific ARI | 0 | 4 [ ^19^ , ^37^ – ^39^ ] | 1 [ ^11^ ] | 2 [ ^20^ , ^25^ ] | 1 [ ^18^ ] | 3 [ ^4^ , ^9^ , ^41^ ] | 11
Acute diarrhea | 1 [ ^16^ ] | 1 [ ^31^ ] | 0 | 0 | 0 | 0 | 2
No specific disease target | 1 [ ^30^ ] | 0 | 0 | 0 | 0 | 5 [ ^2^ , ^6^ , ^10^ , ^29^ , ^34^ ] | 6
Total | 4 | 10 | 1 | 3 | 1 | 15 | 34

Antibiotic treatment studies classified according to target disease and population. “Specific insurance” refers to patients within a health maintenance organization (HMO), other managed care organization, Medicare, or Medicaid.

### Intervention Characteristics

Interventions utilized a variety of combinations of QI strategies targeted at both clinicians and patients. Educational strategies were most commonly used, with 27 trials (from 22 studies ^87,^ ^102^ – ^106,^ ^108^ – ^117,^ ^121,^ ^122,^ ^124^ – ^126,^ ^128^ ) using some form of clinician education and 18 (from 15 studies ^87,^ ^101,^ ^102,^ ^107^ – ^111,^ ^113,^ ^122,^ ^126^ – ^128,^ ^132,^ ^133^ ) using patient education; 12 trials (from 10 studies ^87,^ ^102,^ ^108^ – ^111,^ ^113,^ ^122,^ ^126,^ ^128^ ) provided education to both clinicians and patients. Audit and feedback to individual clinicians or groups of clinicians was used in 12 trials (from 11 studies ^101,^ ^106^ – ^108,^ ^111,^ ^114,^ ^117,^ ^121,^ ^124^ – ^126^ ), frequently in combination with clinician education (N=10 trials ^106,^ ^108,^ ^101,^ ^111,^ ^114,^ ^117,^ ^121,^ ^124^ – ^126^ ). Delayed prescribing was used in five studies, ^129^ – ^133^ clinician reminders in two, ^118,^ ^119^ with patient self-management and financial and regulatory incentives used in one study each ^87,^ ^128^ (both in combination with other strategies). One ^87^ trial used organizational change. No trials used patient reminders or facilitated relay of clinical data. The median number of QI strategies used per trial was two (range one to six), with the majority of trials (N=22) using more than one strategy ( Table 2 ).

Table 2 Antibiotic treatment studies: number of QI strategies utilized

Number of QI strategies | Randomized Controlled Trial | Quasi-RCT | Controlled Before-After Study | Total
One | 15 [ ^2^ – ^4,^ ^7,^ ^8,^ ^10,^ ^19,^ ^21,^ ^22,^ ^25,^ ^26,^ ^28,^ ^31,^ ^32,^ ^41^ ] | 3 [ ^6,^ ^14,^ ^15^ ] | 1 [ ^36^ ] | 19
Two | 6 [ ^20,^ ^23,^ ^24,^ ^29,^ ^33,^ ^38^ ] | 1 [ ^13^ ] | 9 [ ^5,^ ^11,^ ^16,^ ^17,^ ^27,^ ^30,^ ^34,^ ^37,^ ^39^ ] | 16
Three | 2 [ ^1,^ ^40^ ] | 1 [ ^35^ ] | 2 [ ^11,^ ^18^ ] | 5
Four | 0 | 0 | 0 | 0
Five | 0 | 0 | 0 | 0
Six | 1 [ ^9^ ] | 0 | 0 | 1
More than six | 0 | 0 | 0 | 0
Total | 24 | 5 | 12

“Quasi-RCT” refers to studies described as randomized where randomization was altered by investigators, or where a method of patient assignment was used that is not truly random (e.g. assignment by even/odd medical record number or date of clinic visit.) “Controlled Before-After Study” refers to non-randomized controlled trials with a contemporaneous comparison group. Quasi-RCT's and Controlled Before-After studies were grouped together in statistical analyses.

Within the broad categories of patient and clinician education, interventions incorporated a mix of passive and active educational elements. Active educational strategies for clinicians included educational outreach (“academic detailing”), workshops, and consensus-building sessions; active strategies for patients consisted of one-on-one or group interactive educational sessions. More than half of trials (N=17, from 16 studies ^103^ – ^106,^ ^108^ – ^110,^ ^112^ – ^114,^ ^117,^ ^121,^ ^122,^ ^124,^ ^126,^ ^128^ ) using clinician education used at least one active strategy, including educational outreach visits (academic detailing) in 10 trials, workshops in eight trials, and consensus-building sessions in four trials (some trials used more than one of these strategies.) Most clinician education efforts used more than one sub-strategy, such as combining educational outreach visits with distribution of written material. In contrast, patient education approaches were nearly exclusively passive (N=15 trials ^87,^ ^101,^ ^102,^ ^107^ – ^111,^ ^113,^ ^122,^ ^126^ – ^128,^ ^132,^ ^133^ ), using only distribution of written materials. Educational efforts most commonly took place in the clinician's office or another clinical setting, but two studies ^109,^ ^122^ used mass media efforts to attempt to educate the entire population of a geographic area.

The proportion of visits at which an antibiotic was prescribed was the primary outcome in 32 trials (from 25 studies), ^87,^ ^101^ – ^119,^ ^129^ – ^133^ with the remaining studies reporting the total number of antibiotic prescriptions (expressed as either prescriptions per patient or prescriptions per clinician). Scant information was provided on secondary outcomes. The safety of the intervention was addressed in only six trials (from five studies ^87,^ ^108,^ ^111,^ ^131,^ ^133^ ) which reported the effects of the intervention on the rate of return visits; four trials addressed patient satisfaction, ^101,^ ^129^ – ^131^ and four assessed the clinical outcome of the disease being studied. ^112,^ ^129^ – ^131^ No study reported the rate of adverse drug events. Only two studies ^109,^ ^113^ reported the effect of an intervention on antimicrobial resistance, and two other studies ^112,^ ^121^ reported information on the costs of prescribing.

### Quality of Included Studies

The methodologic quality of included studies was generally fair. Most trials were randomized controlled trials (N=24, from 20 studies) ^87,^ ^103,^ ^105,^ ^107,^ ^112,^ ^114,^ ^115,^ ^118^ – ^120,^ ^123^ – ^126,^ ^128^ – ^133^ ; five trials (from three studies) ^101,^ ^110,^ ^116^ used a quasi-randomized design, with allocation altered by the investigators to assure equivalent demographic characteristics between control and intervention groups (e.g., using alternating patients, or even/odd identifying numbers). For analytic purposes, these trials were grouped with the remaining 12 trials, which used a nonrandomized CBA design. Among these 12 trials, only 5 (from four studies ^108,^ ^111,^ ^117,^ ^122^ ) explicitly explained the criteria used for selecting the comparison group. The comparison groups received a low-intensity intervention in seven trials ^118,^ ^119,^ ^121,^ ^125,^ ^130,^ ^132,^ ^133^ and no intervention in 34 trials.

Outcome assessors were clearly defined as being blinded to treatment group assignment in two trials. The unit of analysis and unit of allocation differed in 22 trials; 14 of these trials (in 11 studies ^103,^ ^104,^ ^106^ – ^110,^ ^117,^ ^122,^ ^124,^ ^127^ ) failed to statistically correct for this difference. Prescribing behavior was measured directly by chart review in 18 trials, with the remainder using pharmacy or other administrative databases.

As has been documented in previous reviews of QI studies, included trials frequently failed to describe the theoretical basis for their intervention, and failed to document key intervention and study characteristics. ^51,^ ^134^ Most of the trials (N=28) did not document the extent of the antibiotic prescribing quality gap in their patient population. Few trials explained the rationale for selecting the QI strategies in their intervention, and almost all trials failed to document the reach of the intervention (e.g., the percentage of clinicians who actually attended the educational session). The median length of followup was 6 months (in the 39 trials reporting this information); eight trials had followup of 1 year or greater.

### Effectiveness of Specific QI Strategies and Combinations of Strategies

Table 3 summarizes the median effect size of net changes in antibiotic prescribing rates for the 24 trials that provided sufficient information to calculate effect size, with individual study effect sizes shown in Figure 5 . (The five delayed prescribing trials are summarized separately in Table 6 .) Overall, the calculated median effect size across all QI interventions was -8.9% (IQR -12.4% to -6.7%). The smallest median effect size was seen in the two studies that used patient education only (-4.9%, IQR -9.9% to -0.2%), with slightly greater effects seen in studies using clinician education alone (-8.1%, IQR -13.7% to -7.0%). No single strategy appeared to be more effective than the others (p=0.848 by Kruskal-Wallis test). The two most common intervention types were clinician education only (N=9) or clinician education combined with patient education (N=6). There was no difference in median effects between these two strategies (p=0.478). Twelve studies used multiple QI strategies (six with clinician and patient education, two with clinician education and audit and feedback, one with patient education and audit and feedback, and three with patient education, clinician education, and audit and feedback). Studies using multiple QI strategies were not more effective than those using single strategies (p=0.82 by Wilcoxon rank-sum test).

Figure 5. Net reduction in antibiotic prescribing rate for individual studies (antibiotic treatment studies)

Figure 5 Legend

Effect size for each study (N=24) that supplied sufficient information for analysis. Percentages show the net change in the percentage of visits at which an antibiotic was prescribed, calculated as: Net Δ in prescribing = (Post-intervention prescribing rate - Pre-intervention prescribing rate) _ intervention group _ - (Post-intervention prescribing rate - Pre-intervention prescribing rate) _ control group _ .

Table 3 Median effect size of QI strategies on antibiotic treatment decision

| Median effect with QI strategy (Interquartile range)
All comparisons (N=24) | -8.9% (-12.4% to -6.7%)
Clinician Education alone (N=9) | -8.1% (-13.7% to -7.0)
Clinician Education combined with Patient Education* (N=6) | -7.5% (-12.0% to -3.0%)
Clinician Education combined with Audit and Feedback (N=2) | -8.5% (-15.0% to -2.0%) | P=0.848 for comparison across QI strategies
Clinician Education, Patient Education, and Audit and Feedback (N=3) | -12.0% (-18.0% to -10.9%) | P=0.478 for comparison of clinician education vs. clinician education and patient education
Patient Education alone (N=2)* | -4.9% (-9.9% to -0.2%)
Audit and Feedback alone (N=1) | -7.3%
Patient Education combined with Audit and Feedback (N=1) | -7.2%

Percentages demonstrate the net reduction in prescribing of antibiotics. Values represent the median effect across studies with each QI strategy (or combination of strategies) with interquartile ranges. For categories with N=2, values in parenthesis represent the effects of the two studies in question.

The net change in antibiotic prescribing for each study was calculated as follows:

Net Δ in prescribing = (Post-intervention proportion prescribed antibiotics - Pre-intervention proportion prescribed antibiotics) _ intervention group _ - (Post-intervention proportion prescribed antibiotics - Pre-intervention proportion prescribed antibiotics) _ control group _ .

The median value was then obtained from the values of the net Δ in prescribing for each subset of studies. Median effects for each QI strategy were compared using the nonparametric Kruskal-Wallis test, which tests the equality of each median effect.

* —Includes one study ^10^ with four additional QI strategies (Clinician Reminders, Organizational Change, Financial incentives for Patients, Regulatory Incentives for Clinicians.) No other study utilized any of these QI strategies.

Table 6 Delayed prescription studies

Study | Target condition | Rate of antibiotic use (comparison group) | Rate of antibiotic use (intervention group) | Reduction in antibiotic use (Intervention _ post _ - Control _ post _ )
Arroll et al ^4^ | Common cold | 87.0% | 40.3% | 46.7%
Dowell et al ^8^ | Uncomplicated ARI | 100.0% | 45.0% | 55.0%
Little et al ^19^ | Pediatric otitis media | 98.5% | 24.0% | 74.5%
MacFarlane et al ^20^ | Acute bronchitis | 62.0% | 47.0% | 15.0%
Pshetizky et al ^38^ | Pediatric otitis media | 63.0% | 37.0% | 26.0%

Studies using delayed prescriptions are those in which the antibiotic prescription is provided to the patient with instructions to use the prescription only if their condition did not improve with supportive measures within a set period of time. These studies did not report pre-intervention prescribing rates. In all studies, comparison group patients received antibiotic prescriptions with instructions to begin taking antibiotics immediately; the post-intervention control group percentages refer to the percent of patients who actually filled the prescription. In Dowell et al, the percentage of control group patients who used the antibiotic prescription was not stated. The studies by Macfarlane and Pshetizky also incorporated a brief educational intervention for patients.

Independent of QI strategy, we examined whether any of the selected study characteristics was associated with effect size. To maximize power, we restricted these analyses to the two dominant QI strategies (clinician education vs. clinician education combined with patient education). None of these factors appeared to have a strong influence on the overall effect size ( Table 4 ). With regard to intervention characteristics, trials using active educational strategies appear to have slightly larger median effects (-13.7% compared with -7.0%,) but this relationship was not statistically significant (p=0.11 by Wilcoxon rank-sum test for studies with the two dominant QI strategies ( Table 5 ); p=0.33 for all studies). Repeated interventions also did not exert stronger effects on prescribing behavior. Similarly, non-US studies had greater median effects than studies conducted in the US (median effect -8.9% compared with -3.0%), but this relationship was also not statistically significant (p=0.15 for studies with the two dominant QI strategies). Interventions targeting a specific disease were also not significantly more likely to reduce prescribing than interventions targeting general prescribing (p=0.66). We could not evaluate for the effect of the type of comparison group, as all 15 trials had a no-intervention comparison group.

Table 4 Antibiotic treatment studies: QI strategies and study modifiers

| Median effect overall (Interquartile range) | Provider education alone (N=9) | Provider education and Patient Education (N=6)
All comparisons (N=15) | -8.1% (-6.5% to -13.7%) | -8.1% (-13.7% to -7.0) | -7.5% (-12.0% to -3.0%)
Randomized Controlled Trials N=7 | -7.0% (-13.7% to -6.7%) | -7.0% (-12.0% to -6.8%) N=6 | -3.0% N=1
Controlled Before-After Trials N=8 | -10.8% (-17.7% to -6.8%) | -9.6% (-16.5% to -8.9%) N=3 | -12.0% (-12.0% to -3.0%) N=5
US-based Studies N=3 | -3.0% (-12.0% to1.5%) | N=0 | -3.0% (-7.5% to -0.3%) N=3
Non-US-based Studies N=12 | -8.9% (-16.5% to -6.9%) | -8.1% (-13.7% to -7.0) N=9 | -12.0% (-20.8% to -7.5%) N=3
Effective sample size below median N=12 | -10.8% (-26.0% to -6.8%) | -9.6% (-23.3% to -7.0%) N=5 | -12.0% (-20.8% to -5.3%) N=3
Effective sample size above median N=7 | -7.0% (-12.0% to -3.0%) | -7.6% (-9.5% to -6.9%) N=4 | -3.0% (-7.5% to -0.3%) N=3
Baseline prescription rate below median N=10 | -7.0% (-9.6% to -7.0%) | -10.9% (-20.9% to -7.1%) N=6 | -7.5% (-12.0% to -3.0%) N=4
Baseline prescription rate above median N=5 | -10.5% (-13.7% to -6.5%) | -7.0% (-8.3% to -7.0%) N=3 | -14.0% (-29.5% to 1.5%) N=2
Repeated intervention N=5 | -8.1% (-12.0% to -7.1%) | -7.0% (-7.6% to -7.0%) N=3 | 12.0% (-12.0%, -12.0%) N=2
One-time intervention N=10 | 8.2% (-23.3% to -3.0%) | -11.7% (-20.9% to -7.4%) N=6 | -3.0% (-9.6% to -1.9%) N=4
Active educational strategy used N=7 | -13.7% (-28.6% to -6.5%) | -18.6% (-24.5% to -11.9%) N=4 | -12.0% (-20.8% to -5.3%) N=3
Only passive educational strategies used N=8 | -7.0% (-8.9% to -4.9%) | -7.1% (-8.1% to -7.0%) N=5 | -3.0% (-7.5% to -0.3%) N=3
Specific disease targeted (N=12) | -10.8% (-4.5% to -18.4% | -11.7% (-20.9% to -7.4%) N=6 | -7.5% (-12.0% to -3.0% N=6
No specific disease targeted (N=3) | -7.0% (-8.1% to -7.0%) | -7.0% (-8.1% to -7.0%) N=3 | N=0
Children targeted (N=6) | -10.8% (-13.7% to -6.7%) | -9.6% (-11.7% to -8.2%) N=3 | -12.0% (-20.8% to -5.3%) N=3
Children not targeted (N=9) | -7.0% (-12.0% to -6.5%) | -7.6% (-19.5% to -6.9%) N=6 | -3.0% (-7.5% to -3.0% (N=3)

Table 4 includes only the QI strategies used in >3 trials. Trials designated as quasi-Randomized Controlled Trials in Table 2 are grouped with Controlled Before-After studies in these analyses.

Table 5 Results of Wilcoxon rank-sum tests for differences between groups

| Treatment studies (N=15) | | | Selection studies (N=19)
| | Median effect (%)[Interquartile range] | P value for comparison | | Median effect (%)[Interquartile range] | P value for comparison
Study design | RCT (n = 7) | -7.0% (-13.7% to -6.7%) | 0.52 | RCT (n = 8) | 11.1% (3.2% to 16.0%) | 0.62
| Non-RCT (n = 8) | -10.8% (-17.7% to -6.8%) | | Non-RCT (n = 11) | 8.8% (3.1% to 22.7%)
Sample Size | Below median (n = 8) | -10.8% (-26.0% to -6.8%) | 0.30 | Below median (n = 7) | 20.4% (8.4% to 35.6%) | 0.063
| Above median (n = 7) | -7.0% (-12.0% to -3.0%) | | Above median (n = 12) | 6.2% (2.8% to 13.7%)
Country | US (n = 3) | -3.0% (-12.0% to1.5%) | 0.15 | US (n = 4) | 29.2% (14.9% to 41.8%) | 0.028
| Non-US (n = 12) | -8.9% (-16.5% to -6.9%) | | Non-US (n = 15) | 8.4% (2.5% to 14.9%)
Type of control group | Usual care (N=15) | Not performed | N/A | Usual care (N=14) | 14.4% (7.2% to 20.4%) | 0.041
| Limited intervention (n = 0) | Not performed | | Limited intervention (n = 5) | 3.1% (2.5% to 7.1%)
Baseline prescribing rate | Below median (N=5) | -7.0% (-9.6% to -7.0%) | 0.82 | Below median (N=9) | 13.9% (3.1% to 17.0%) | 0.87
| Above median (N=10) | -10.5% (-13.7% to -6.5%) | | Above median (N=10) | 8.6% (4.3% to 20.4%)
Use of active educational strategies | Yes (N=7) | -13.7% (-28.6% to -6.5%) | 0.11 | Yes (N=12) | 11.1% (4.9% to 17.1%) | 0.87
| No (N=8) | -7.0% (-8.9% to -4.9%) | | No (N=7) | 5.1% (3.1% to 22.7%)
Repeated intervention | Yes (N=5) | -8.1% (-12.0% to -7.1%) | 0.81 | Yes (N=8) | 6.8% (3.7% to 14.8%) | 0.37
| No (N=16) | 8.2% (-23.3% to -3.0%) | | No (N=11) | 13.9% (2.5% to 22.7%)
Specific disease targeted | Yes (N=12) | -10.8% (-4.5% to -18.4% | 0.66 | Yes (N=17) | 12.5% (3.1% to 18.6%) | 0.19
| No (N=3) | -7.0% (-8.1% to -7.0%) | | No (N=2) | 3.4% (2.5% to 4.3%)
Children targeted | Yes (N=6) | -10.8% (-13.7% to -6.7%) | 0.60 | Yes (N=2) | 29.2% (22.7% to 35.6%) | 0.05
| No N=9) | -7.0% (-12.0% to -6.5%) | | No (N=17) | 8.4% (3.1% to 13.9%

Results of nonparametric Wilcoxon rank-sum tests the hypothesis that the median effects in the two groups being compared are equal. This analysis is restricted to the subgroup of studies in the two dominant QI strategies: for treatment studies, clinician education and clinician education plus patient education; for selection studies, clinician education and clinician education plus audit and feedback. Trials designated as quasi-Randomized Controlled Trials in Table 2 are grouped with Controlled Before-After studies in these analyses.

We further stratified the studies by study design and sample size to assess if these factors correlated with median effect size. No statistically significant relationship was found for either variable (p=0.77 and 0.75 respectively). We also hypothesized that trials with higher baseline rates of prescribing antibiotics might be more likely to demonstrate significant effects (the “low-hanging fruit” effect); this also was not borne out (p=0.82).

As we did not observe a difference in median effects among QI strategies, our assessment of potential confounding by moderating factors and study biases amounts to evaluating for potential negative confounding, which would result in a spurious finding of no difference among groups ( Table 5 ). We identified study design (RCT vs. CBA) and study location (US vs. other) as meeting the threshold of association (P<0.20) with the dominant QI strategies (clinician education vs. clinician and patient education). However, neither of these factors was significantly associated with overall median effects (P=0.52 and 0.15, respectively), eliminating them as confounders. We did not find evidence that the presence or absence of our prespecified quality criteria affected study results, as there was no significant difference in median effects for studies with or without any of the internal validity or translatability elements. For example, studies where prescribing was measured by chart review showed no difference in median effects than studies in which prescribing was measured by other means (median effect -9.6% and -7.3%, respectively; p=0.47.); and as noted above, no difference was found in median effects between randomized and nonrandomized studies.

### Delayed Prescription Studies

Five studies used delayed prescriptions, where patients were asked to fill their prescription after a specified period of time if their symptoms did not improve, as the primary strategy to reduce antibiotic use, with two of these studies ^132,^ ^133^ also incorporating a patient educational intervention ( Table 6 ). All trials evaluated ARIs, with two studies enrolling children with otitis media, ^129,^ ^132^ and one each evaluating adults with the “common cold,” ^130^ acute cough, ^131^ and acute bronchitis. ^133^ These trials enrolled and randomized patients judged to not need antibiotics by the treating physician. Notably, these trials were methodologically sound: all trials were RCTs (randomized by patient) and had prescribing measured by chart review. Antibiotic use was measured by patient report in three studies ^130,^ ^132,^ ^133^ ; in two, patients in the intervention group were required to return to the office to collect their prescription. ^129,^ ^131^ All had sample sizes below the median for all treatment studies.

For these studies, we calculated the post-intervention difference between antibiotic use in the intervention group and the control group. The median difference was -46.7% (IQR -55.0% to -26.7%), indicating a marked reduction in antibiotic use in the intervention groups; however, the post-intervention median rate of antibiotic use in the control groups was still 87.0% (IQR 63.0% to 98.5%). This raises the possibility that delayed prescribing strategies may appear more effective only because of artificially high rates of antibiotic use in the comparison group (since the protocols called for near-universal antibiotic treatment in the control group), which under non-study conditions might have had a lower antibiotic prescription rate.

### Studies Not Eligible for Median Effect Size Analysis

Twelve studies ^117^ – ^128^ met all of our inclusion criteria, but did not report outcomes in a fashion compatible with those included in the median effects analysis. Six of these studies ^120^ – ^122,^ ^125,^ ^126,^ ^128^ targeted overall antibiotic prescribing, while five targeted upper respiratory infections, ^118,^ ^119,^ ^123,^ ^124,^ ^127^ and one ^117^ acute diarrhea. Four studies ^122,^ ^123,^ ^126,^ ^127^ exclusively addressed prescribing of antibiotics to children. The overall methodologic quality of these trials was variable. Eight ^118^ – ^120,^ ^123^ – ^126,^ ^128^ of the 12 studies were RCTs, and all four nonrandomized trials clearly explained the rationale for selection of the comparison group. However, only one study ^120^ documented blinding of outcome assessors. The baseline quality gap was documented in only three studies ^122,^ ^124,^ ^126,^ and only two studies ^118,^ ^119^ measured prescribing rates by chart review, with the others all using administrative claims data.

Five of the trials addressing general prescribing used multi-faceted strategies involving combinations of patient education, clinician education, and audit and feedback to address antibiotic use in large patient and clinician populations. Two of these ^121,^ ^125^ delivered a combined clinician education and audit and feedback intervention to all clinicians in a geographic area, either via passive mailings ^125^ or through interactive workshops ^121^ ; neither documented a significant reduction in overall antibiotic use. Combinations of patient and clinician education were used in two studies. A reduction of 1.13 prescriptions per 100 visits was achieved in an Australian study ^128^ that used consensus-building sessions and a clinical guideline as well as patient education. Perz et al ^122^ delivered an educational intervention to patients and clinicians, with use of educational outreach and mass media efforts, and achieved an 11% intervention-attributable reduction in antibiotic prescription rates (a decrease of about 0.16 antibiotic courses per Medicaid managed care child [0–15 years of age] per year). Finkelstein et al ^126^ combined active clinician education, audit and feedback, and patient education to achieve reductions of about 0.06 antibiotic courses per commercial managed care enrolled child (0–5 years of age) per year.

Clinician reminders were used in three studies. ^118,^ ^119,^ ^123^ Christakis et al ^123^ used a computer-delivered reminder for prescribing in pediatric otitis media; there was no significant reduction in overall antibiotic use, but the intervention did lead to a significant improvement in prescribing for the appropriate duration of therapy. McIsaac et al ^118,^ ^119^ conducted two separate studies using a chart-based reminder to use a validated scoring system for antibiotic prescribing in sore throat cases, but both failed to significantly reduce prescribing.

Active clinician education and audit and feedback interventions were used for two condition-specific studies. One ^124^ achieved a reduction of 6.4 prescriptions per clinician per 6 months for ARIs. Another, ^117^ targeting prescribing behavior in acute diarrhea, demonstrated absolute reductions of 15.2% for antibiotic prescribing and 20.2% for antiparasitics in the intervention group, but comparable comparison group values were not provided. Pediatric otitis media was addressed in another study using delayed prescribing ^127,^ which achieved a significant reduction of 17 prescriptions per clinic per month. Finally, one study ^120^ (the Rand Health Experiment) allocated patients to either a free or cost-sharing insurance plan. Antibiotic use decreased by 0.43 antibiotic courses per insured person (non-elderly families) per year in the cost-sharing group.

### Population Effect Size

In this analysis, we found that interventions targeting all ARIs in adults ( Figure 6 ) translate into the largest effects at the general population level, with savings of 35–85 antibiotics per 1000 person-years. In the median effects analysis, these studies appear to have only modest effect sizes, but the larger population to which they apply outweighs the modest effect. Conversely, highly effective condition-specific interventions (or interventions targeting children) may not project to large reductions in prescribing at the population level. Two studies not included in the median effects analysis can also be compared in this manner. At the population level, Perz et al ^122^ extrapolate to 23 antibiotic courses saved per 1000 per person-year, and Finkelstein et al ^126^ to five antibiotic courses saved per 1000 per person-year ( Figure 6 ).

Figure 6. Population-level effect of studies targeting the antibiotic treatment decision

Figure 6 Legend

Bars show the potential antibiotic prescriptions saved per 1000 person-years of observation for each individual study. Studies are grouped by target condition and target population. These results were extrapolated from individual study effect sizes based on visit rates from the 2002 NAMCS survey and census data. Percentages show the individual study effect size, expressed as net change in the percentage of visits at which an antibiotic was prescribed.

*Studies by Perz et al and Finkelstein et al reported continuous data (antibiotics prescribed per person-year) so effect sizes are not provided.

For a 100,000-member health maintenance organization (HMO), these studies suggest that a QI strategy targeting all ARIs for patients of all age groups would result in a savings of approximately 3000 to 8000 antibiotic prescriptions per year. Figure 7 shows the range of antibiotic cost savings that could be obtained from reducing antibiotic prescribing across a range of population-level reductions in prescribing and antibiotic cost estimates. These cost estimates do not take into account the implementation cost of the intervention itself. Assuming average costs of $30 – $50 per antibiotic prescription, the organization would save between $90,000 and $400,000 in antibiotic costs ( Figure 7 ).

Figure 7. Projected cost savings from antibiotic treatment interventions

Figure 7 Legend

This figure represents the potential savings in antibiotic costs that could be obtained through reductions in antibiotic prescribing, for a 100,000 member Health Maintenance Organization (HMO). The reduction in antibiotic prescribing is expressed as number of antibiotic prescriptions saved per 1000 person-years of observation. Costs are expressed as thousands of dollars saved.

### Within-Study Comparisons

In five studies, investigators examined more than one type of intervention. These five studies ^103,^ ^107,^ ^110,^ ^111,^ ^115^ evaluated a total of nine comparisons of intervention and comparison groups. In two studies ^103,^ ^115^ the interventions consisted of either passive or active clinician education; in both cases, the active education intervention resulted in a significantly larger effect size. Another study ^107^ evaluated three strategies: passive patient education alone, audit and feedback alone, or both strategies. The absolute rate of antibiotic prescribing increased in all intervention groups, although the rate of increase was significantly less in the groups receiving patient education. Another study evaluated three comparisons ^110^ : intervention groups received either active clinician education, passive patient education, or a combination of both strategies. The largest absolute reduction in prescribing was found in the combined strategy group, with no overall reduction found in the patient education only group. Finally, a study examining acute bronchitis in adults ^111^ carried out a “limited intervention” consisting of passively distributed educational materials targeted at patients and clinicians, and a “full intervention” with active clinician education, audit and feedback, and patient education. The full intervention resulted in a significant reduction in prescribing, while the limited intervention had no overall effect.

### Special Populations and Secondary Endpoints

The median effect size of interventions targeted at children was not significantly different from interventions as a whole (median effect size -8.5% for 10 trials targeting children, -8.9% in the 14 trials not targeting children). The QI strategies used in these 10 trials were similar to the overall distribution, with two trials ^107,^ ^110^ using patient education alone (targeted at parents of children), three using patient education combined with clinician education, ^102,^ ^110,^ ^113^ three using clinician education alone, ^103,^ ^110^ and one trial each (from the same study ^107^ ) using audit and feedback alone and patient education combined with audit and feedback. Eight ^117,^ ^122,^ ^123,^ ^126^ – ^129,^ ^132^ studies not used in our median effects analyses targeted children, including three studies ^127,^ ^129,^ ^132^ using delayed prescribing strategies for childhood otitis media; as discussed earlier, all showed much lower relative rates of antibiotic use. The other five studies included three community-based studies using multifaceted strategies discussed above ^122,^ ^126,^ ^128,^ all of which significantly reduced antibiotic prescribing; one condition-specific study using reminders that failed to reduce prescribing ^123,^ and one condition-specific study using a multifaceted information which reported only intervention group data. ^117^

Two studies ^109,^ ^113^ reported rates of antimicrobial resistance. Both trials used combined patient and clinician educational strategies to target antibiotic use at the community level. Although both exerted positive effects on overall antimicrobial use, the percentage of drug-resistant organisms (penicillin-resistant S. pneumoniae ) did not significantly change in either case. The length of followup was 6 months in both studies, which may have been too short to detect significant changes.

Two studies assessed costs of antibiotic prescribing. One study, ^121^ which failed to document an overall reduction in antibiotic prescribing at the community level did show a reduction in total prescribing costs of 18.1% in the intervention group relative to control. An increase in the use of narrow-spectrum antibiotics may have been responsible for this savings. A Belgian study ^102^ using an active clinician educational intervention reduced antibiotic prescribing for acute cough and achieved a reduction in prescribing costs of 6.97 euros (approximately $9) per patient. The calculated antibiotic cost reductions in both these studies did not take into account the costs of the interventions themselves.

The safety of the intervention was addressed in seven trials (from six studies) ^87,^ ^108,^ ^111,^ ^112,^ ^131,^ ^133^ that measured post-intervention use of health services. Five of these (from four studies) ^111,^ ^112,^ ^131,^ ^133^ measured the rate of return office visits, and none found more return visits in the intervention group. One study ^87^ found no difference in the need for telephone consultation between groups. The only study that found a possible increase in health services utilization ^108^ documented a slight increase in the prescribing of antibiotics at a return visit if the patient did not receive antibiotics originally. The rate of return visits was not different, however. Four studies, ^112,^ ^129^ – ^131^ three of which used delayed prescribing, measured the time to symptom resolution through patient interviews or diaries; none found a greater overall duration of patient symptoms if patients did not receive antibiotics, although one study ^129^ of delayed prescribing in children with otitis media found a greater duration of distress in the delayed group. Four studies measured patient satisfaction ^101,^ ^129^ – ^131^ ; fewer patients were “very satisfied” with treatment in one study ^131^ of delayed prescribing, but no difference was present in the other studies. Adverse drug events were measured in only one study, ^129^ which found significantly less diarrhea in patients not receiving antibiotics, but no difference in the incidence of rash.

## Studies To Improve the Antibiotic Selection Decision

### Studies Meeting Inclusion Criteria

Twenty-six studies ^102,^ ^104,^ ^106,^ ^112,^ ^114,^ ^121,^ ^135^ – ^154^ on antibiotic selection, reporting data on 33 trials, met inclusion criteria for this review ( Table 1B ). Of these 33 trials, 22 (from 20 studies) ^102,^ ^104,^ ^106,^ ^112,^ ^114,^ ^121,^ ^137,^ ^138,^ ^140^ – ^145,^ ^147,^ ^149^ – ^151,^ ^153,^ ^154^ reported outcome data that allowed inclusion in the median effects analyses, including 19 that reported data on patient sample size. The remaining three trials ^114,^ ^140,^ ^143^ listed information on cluster sizes, from which an approximate sample size could be estimated; each of these three sample sizes were above the median sample size calculated from the other 19 trials. The 11 trials not suitable for median effects analysis were from six studies. ^135,^ ^136,^ ^139,^ ^146,^ ^148,^ ^152^ Four of these studies ^136,^ ^139,^ ^146,^ ^148^ did not report complete pre-intervention and post-intervention data, reporting only the percentage change. Of the other two, one study reported count data ^152^ and the other continuous data (antibiotic prescriptions per provider), ^135^ neither of which could be combined with dichotomous data.

### Setting, Goals, and Target Population of Studies

Appendix B * contains summaries of each included study, grouped by measured population. The study intervention and results are summarized in these tables as well.

Most studies (21) were conducted outside of the United States, including 12 from Europe, ^102,^ ^104,^ ^106,^ ^112,^ ^121,^ ^136,^ ^141,^ ^146,^ ^147,^ ^151,^ ^153,^ ^154^ four from Australia, ^114,^ ^138,^ ^144,^ ^149^ three from Canada, ^139,^ ^143,^ ^148^ and two from other countries. ^142,^ ^150^ Nearly all (22) were conducted in primary care settings. Other intervention sites included emergency rooms (one study), urgent care or walk-in clinics (one study), and other settings (two studies) ^141,^ ^148^ ; no interventions targeted specialists' offices. All but four studies reported the study dates; midpoints ranged from 1975 to late 2000, with 13 studies occurring over the past decade.

All studies focused on reducing the use of broad-spectrum or costly antibiotics or improving the selection of certain recommended antibiotics over others; no interventions attempted to increase the use of broad-spectrum or expensive agents in the face of increased antibiotic resistance. Four studies attempted to shorten the duration of prescriptions for acute illnesses, including one for which this was the exclusive antibiotic utilization outcome measured. No studies attempted to increase the duration of prescriptions. No studies focused on improving antibiotic dosing.

The 26 eligible studies examined a variety of populations and conditions ( Table 1D ). Several studies focused on special patient populations, including elderly patients (two), ^143,^ ^148^ children (three) ^102,^ ^137,^ ^144^ (including one ^137^ specifically on children in an HMO), and a Medicaid population (one). ^135^ Respiratory tract infections were the most commonly targeted condition (13 studies), ^102,^ ^104,^ ^106,^ ^112,^ ^114,^ ^137^ – ^141,^ ^144,^ ^150,^ ^153^ followed by urinary tract infections (eight), ^136,^ ^144^ – ^147,^ ^149,^ ^151,^ ^154^ and sexually transmitted diseases (one) ^142^ ; one study examined both ARI and UTI prescribing. ^144^ Six studies did not examine a specific condition. ^121,^ ^135,^ ^141,^ ^143,^ ^148,^ ^152^ Among 22 trials included in the median effects analysis, baseline rates of prescribing of recommended antibiotics in the comparison group ranged from 20% to 90% with a median of 57%.

Table 1D Antibiotic selection studies: target condition and population

| Studies targeting children | | Studies targeting adults | | Studies targeting entire population | | Total
| Specific insurance | No specific insurance | Specific insurance | No specific insurance | Specific insurance | No specific insurance
General ARI | 0 | 0 | 0 | 0 | 1 [ ^50^ ] | 5 [ ^36^ , ^54^ , ^67^ , ^69,^ ^71^ ] | 6
Specific ARI | 1 [ ^46^ ] | 2 [ ^39^ , ^49^ ] | 0 | 0 | 0 | 3 [ ^41^ , ^48^ , ^61^ ] | 6
Urinary tract infection | 0 | 0 | 0 | 6 [ ^55^ – ^57^ , ^60,^ ^62^ , ^68^ ] | 0 | 2 [ ^44^ , ^45^ ] | 8
Other disease | 0 | 0 | 0 | 1 [ ^70^ ] | 0 | 0 | 1
No disease target | 0 | 0 | | 2* [ ^53^ , ^58^ ] | 2 [ ^42^ , ^63^ ] | 2 [ ^34^ , ^51^ ] | 6
Total | 1 | 2 | 0 | 9 | 3 | 12 | 26

Antibiotic selection studies classified according to target disease and population. “Specific insurance” refers to patients within a health maintenance organization (HMO), other managed care organization, Medicare or Medicaid.

* —These studies both targeted elderly patients.

### QI Strategy Characteristics

Nearly all trials (30, from 23 studies) were targeted exclusively at clinicians, including 18 trials (from 13 studies ^104,^ ^106,^ ^112,^ ^135,^ ^137^ – ^140,^ ^144,^ ^145,^ ^149,^ ^150,^ ^152^ ) that provided clinician education only, nine trials ^114,^ ^121,^ ^136,^ ^141,^ ^143,^ ^146,^ ^147,^ ^153,^ ^154^ that combined clinician education with audit and feedback, and two trials (from one study ^136^ ) that provided both of the above as well as a regulatory intervention directed at providers. In addition, one trial provided audit and feedback alone. ^151^ The remaining three trials provided both patient and clinician interventions, including a combination of clinician and patient education (two trials) ^102,^ ^142^ and a combination of financial and regulatory interventions directed at clinician and patients (one trial). ^148^ No trials targeted patients exclusively, and none targeted the community.

The median number of QI strategies per trial was one ( Table 7 ); 12 trials used two QI strategies and two trials employed three distinct QI strategies.

Table 7 Antibiotic selection studies: number of QI strategies utilized

Number of QI strategies | Randomized Controlled Trial | Interrupted Time Series | Controlled Before-After Study | Total
One | 6 [ ^41^ – ^43,^ ^48,^ ^49,^ ^54^ ] | 0 | 13 [ ^36,^ ^46,^ ^47,^ ^51,^ ^52,^ ^55,^ ^60^ – ^66^ ] | 19 [ ^36,^ ^41^ – ^43,^ ^46,^ ^47,^ ^48,^ ^49,^ ^51,^ ^52,^ ^54,^ ^55,^ ^60^ – ^66^ ]
Two | 7 [ ^53,^ ^56,^ ^57,^ ^67,^ ^68,^ ^70,^ ^71^ ] | 1 [ ^58^ ] | 4 [ ^34,^ ^50,^ ^69,^ ^73^ ] | 12 [ ^34,^ ^50,^ ^53,^ ^56^ – ^58,^ ^67^ – ^71,^ ^73^ ]
Three | 0 | 0 | 2 [ ^44,^ ^45^ ] | 2 [ ^44,^ ^45^ ]
Four | 0 | 0 | 0 | 0
Five | 0 | 0 | 0 | 0
Six | 0 | 0 | 0 | 0
More than six | 0 | 0 | 0 | 0
Total | 13 [ ^41^ – ^43,^ ^48,^ ^49,^ ^53,^ ^54,^ ^56,^ ^57,^ ^67,^ ^68,^ ^70,^ ^71^ ] | 1 [ ^58^ ] | 19 [ ^34,^ ^36,^ ^44^ – ^47,^ ^50^ – ^52,^ ^55,^ ^60^ – ^66,^ ^69,^ ^73^ ]

There were no quasi-RCT's among the antibiotic selection studies. Interrupted Time Series studies were required to report a clearly defined intervention time period, at least three data points before and after the intervention, and use appropriate statistical methodology. “Controlled Before-After Study” refers to non-randomized controlled trials with a contemporaneous comparison group.

Among the 31 trials involving clinician education, 25 involved distribution of educational materials to clinicians, and six used meetings in which physicians were passive participants. In addition, at least one “active” educational strategy was employed in 20 trials (from 13 studies ^112,^ ^114,^ ^136^ – ^140,^ ^142,^ ^144,^ ^146,^ ^147,^ ^149,^ ^152^ ) involving clinician education, including educational outreach (13 trials from 11 studies ^112,^ ^114,^ ^136,^ ^138^ – ^140,^ ^142,^ ^144,^ ^149,^ ^150,^ ^152^ ), educational workshops (seven trials ^121,^ ^140,^ ^142,^ ^146,^ ^147,^ ^153,^ ^154^ ), and consensus-building sessions (three trials ^104,^ ^137,^ ^146^ ). Among trials providing education, approximately two-thirds (20) provided the education at the clinician's office or workplace; three provided off-site education, and the remainder did not clearly specify the site.

Several different antibiotic utilization outcomes were reported, often in the same study. These include the percentage of patients receiving a recommended antibiotic (14 trials) or being in compliance with a clinical guideline for prescribing (10 trials), antibiotic dose or prescription duration (four trials), and other outcomes (six trials). Outcomes other than antibiotic utilization were reported infrequently, including antibiotic cost data in four studies ^121,^ ^140,^ ^143,^ ^144^ and clinician satisfaction in one trial. ^140^ No studies provided data on clinical outcomes, health services utilization, or antimicrobial resistance.

### Quality of Included Studies

Many of the studies did not meet most of the prespecified quality criteria. Randomized controlled designs were used in 13 trials (from 12 studies), ^112,^ ^114,^ ^135,^ ^138,^ ^139,^ ^142^ – ^144,^ ^146,^ ^147,^ ^153,^ ^154^ 19 used CBA designs(from 13 studies), ^102,^ ^104,^ ^106,^ ^121,^ ^136,^ ^137,^ ^140,^ ^141,^ ^145,^ ^149^ – ^152^ and one employed an ITS design. ^148^ Among 19 trials using a non-randomized comparison group, nine described the rationale for selection of the comparison population.

Treatment assignment was frequently allocated at levels (i.e., clinician, clinic, community) that differed from the unit of analysis (i.e., patient; N=16 studies). In nine of these studies ^104,^ ^137,^ ^140^ – ^143,^ ^145,^ ^151,^ ^152^ investigators failed to statistically correct for differences between the unit of analysis and unit of allocation. Antibiotic prescribing outcomes were assessed using chart review data in nine trials; another 21 used administrative data, and three used other methods.

Nine trials reported empiric evidence for a quality gap in the population under study. Usual care was provided to the control group in 24 trials, whereas in nine the comparison group received some form of low-intensity intervention.

The duration of study followup (either following or concurrent with the study) was less than 1 year in 21 trials. The remaining eight trials that provided this data reported followup periods ranging from 1 – 1.5 years.

### Effect of Interventions on Antibiotic Selection

Table 8 summarizes the median effect of each type of intervention on selection of recommended antibiotics in the 22 interventions that reported results in a manner suitable for this approach. (Individual study effect sizes are shown in Figure 8 .) The median absolute effect was a 10.6% net improvement (IQR 3.4% – 18.2%) in the rate of recommended antibiotic prescribing in intervention groups compared with comparison groups. Clinician education combined with audit and feedback had the smallest median effect (3.4%), while the combination of clinician and patient education had the largest effect (22.8%). These differences in median effect sizes were not statistically significant (P=0.18). However, the efficiency of this statistical test is impaired by the presence of two groups (clinician education combined with patient education, and audit and feedback alone) with low sample sizes (two and one, respectively) in each group. To limit the effect of intervention types with small sample sizes on the tests of significance, we compared the two QI strategies for which more than three trials contributed data (the “dominant” QI strategies); in this subset of studies, clinician education alone was more effective than clinician education combined with audit and feedback (13.9% vs. 3.4%, P=0.03).

Figure 8. Population-level effect of studies targeting the antibiotic treatment decision

Figure 8 Legend

Effect size of each study (N=22) that supplied sufficient information for analysis. Percentages show the net change in percentage of patients prescribed a recommended antibiotic, calculated as: Net Δ in prescribing = (Post-intervention prescribing rate - Pre-intervention prescribing rate) _ intervention group _ - (Post-intervention prescribing rate - Pre-intervention prescribing rate) _ control group _ .

Table 8 Median effect size of QI strategies on antibiotic selection decision

| Median effect with QI strategy (Interquartile range)
All comparisons (N=22) | 10.6% (3.4% to 18.2%)
Clinician Education alone (N=11) | 13.9% (8.6% to 21.6%) | p=0.182 for comparison across QI strategies
Clinician Education combined with Audit and Feedback (N=8) | 3.4% (1.8% to 9.7%) | p=0.028 for comparison of clinician education alone with clinician education and audit and feedback
Clinician Education combined with Patient Education (N=2)* | 22.8% (2.4% to 43.1%)
Audit and Feedback alone (N=1) | 13.9%

Percentages demonstrate the net improvement in selection of the appropriate antibiotic. Values represent the median effect across studies with each QI strategy (or combination of strategies) with interquartile ranges. (For clinician education combined with audit and feedback, values in parenthesis represent the effects of the two studies in question.) Median effects were compared using the nonparametric Kruskal-Wallis test, which evaluates the null hypothesis that the observed effects are from the same study population. Individual study effect sizes calculated as:

Net Δ in prescribing recommended antibiotic = (Post-intervention recommended prescribing percentage - Pre-intervention recommended prescribing percentage) _ intervention group _ - (Post-intervention recommended prescribing percentage - Pre-intervention recommended prescribing percentage) _ control group _ .

Table 9 shows the distribution of potential confounders of the association between QI strategy and effect on prescribing for the two dominant intervention types. Among these 19 trials, the absolute difference in effect between each confounder stratum ranged from 2.3% for RCTs vs. CBA trials, to 20.8% for trials conducted inside vs. outside the US. In our assessment of potential confounders, three study characteristics were not evenly distributed across our “dominant” QI strategies: study design (RCT vs. CBA, p=0.18 by Fisher's exact test), sample size (above vs. below the median, p=0.15), and target disease (specific disease targeted vs. general prescribing targeted, p=0.16).

Table 9 Selection studies: QI strategies and study modifiers

| Median effect overall (Interquartile range) | Provider Education alone (N=11) | Provider Education and Audit and Feedback (N=8)
All comparisons (N=19) | 8.8% (3.1% to 18.6%) | 13.9% (8.4% to 22.7%) | 3.4% (1.5% to 12.1%)
Randomized Controlled Trials N=8 | 11.1% (3.2% to 16.0%) | 13.9% (11.2% to 14.4%) N=3 | 4.3% (2.0% to 17.0%) N=5
Controlled Before-After Trials N=11 | 8.8% (3.1% to 22.7%) | 16.5% (7.8% to 25.9%) N=8 | 2.5% (2.5% to 4.7%) N=3
US-based studies N=4 | 29.2% (15.0% to 41.8%) | 35.6% (29.2% to 41.8%) N=3 | 7.2% N=1
Non-US-based studies N=15 | 8.4% (2.5% to 14.9%) | 10.6% (7.6% to 14.2%) N=8 | 4.9% (1.4% to 14.6%) N=7
Effective sample size below median N=7 | 20.4% (8.4% to 35.6%) | 21.6% (15.5% to 32.4%) N=6 | -7.8% N=1
Effective sample size above median N=12 | 6.2% (2.8% to 13.7%) | 8.8% (5.1% to 12.5%) N=5 | 4.3% (2.1% to 12.1%) N=7
Baseline compliance below median N=9 | 13.9% (3.1% to 17.0%) | 13.9% (5.1% to 14.9%) N=5 | 9.8%2.4% to 17.4% N=4
Baseline compliance above median N=10 | 8.6% (4.3% to 20.4%) | 16.5% (9.1% to 22.5%) N=6 | 2.7% (-1.2% to 5.0%) N=4
Repeated intervention N=8 | 6.8% (3.7% to 14.8%) | 6.8% (4.6% to 9.4%) N=4 | 10.7% (3.5% to 17.0%) N=4
One-time intervention N=11 | 13.9% (2.5% to 22.7%) | 20.4% (14.4% to 29.2%) N=7 | 2.3% (-0.4% to 3.7%) N=4
Active provider educational strategy used N=12 | 11.4% (4.8% to 17.8%) | 14.4% (10.0% to 19.0%) N=6 | 4.9% (1.4% to 14.6%) N=6
Only passive provider educational strategies used N=7 | 5.1% (3.1% to 22.7%) | 12.5% (5.1% to 22.7%) N=5 | 3.2% (0.2% to 4.3%) N=2
Control group received no intervention N=14 | 14.4% (7.2% to 20.4% | 17.7% (3.6% to 25.9%) N=8 | 5.8% (1.8% to 14.6%) N=6
Control group received low-intensity intervention N=5 | 3.1% (2.1% to 5.1%) | 5.1% (4.1% to 6.8%) N=3 | 2.3% (2.0% to 2.5%) N=2
Studies targeting a specific disease N=17 | 12.5% (3.1% to 18.6%) | 13.9% (8.6% to 21.6%) N=11 | 4.3% (1.3% to 14.6%) N=6
Studies not targeting a specific disease N=2 | 3.4% (2.5% to 4.3%) | N=0 | 3.4% (3.0% to 3.9%) N=2
Studies targeting children N=2 | 29.2% (22.7% to 35.6%) | 29.2% (22.7% to 35.6%) N=2 | N=0
Studies not targeting children N=17 | 8.4% (3.1% to 13.9% | 12.5% (8.4% to 14.9%) N=9 | 3.4% (1.8% to 9.7%) N=8

Table includes only the QI strategies used in >3 trials.

Table 5 shows the effect of these potential confounders on the median effect size. Although randomized and non-randomized interventions were unevenly distributed across the two dominant QI strategies, this uneven distribution did not appear to impact the median effect size of these QI strategies (p=0.62 for difference in median effect size). The median effects of interventions targeting prescribing in general was also not significantly different from interventions targeting a specific disease (p=0.19). However, interventions with below-median sample size showed a greater median effect size than those with above-median sample size (P=0.06 for difference). As almost all clinician education combined with audit and feedback interventions were above the median sample size (compared with about half of the clinician education-alone interventions), the presence of positive confounding must be considered (i.e., the larger median effect size for clinician-education alone interventions compared with clinician education and audit and feedback can be partially explained by the greater number of above-median sample size studies in the latter group).

Study country and type of comparison group were also significantly associated with median effect size, with trials conducted inside the US and trials employing a “usual care” comparison group showing greater median effect sizes than their counterparts (P<0.05 for comparison with non-US interventions and interventions using a “limited intervention” control group, respectively; Table 5 ). However, because these study characteristics were evenly distributed among interventions employing the dominant QI strategies, they did not meet our criteria as a confounder of the relationship between QI strategy and outcome effect. Other potential confounders that did not have a significant impact on median effect size included baseline prescribing rate, use of active vs. passive educational strategies, and single vs. repeated interventions (P>0.2 for all). Only one study ^137^ targeted children, and the two trials comprising this study reported larger effects than studies not targeting children. With regard to our prespecified quality criteria, no factors potentially affecting internal validity had a significant effect on median effects, nor did factors potentially affecting translatability.

No studies attempted to increase the use of broad-spectrum antibiotics (e.g., in the face of resistant organisms), so we were unable to compare the efficacy of such interventions with those that aimed to decrease broad-spectrum antibiotic use.

### Studies of Duration of Antibiotic Therapy

Four studies evaluated the effect of interventions on reducing the duration ^146,^ ^147,^ ^151,^ ^154^ of antibiotic prescriptions, all for women with UTIs. Three of these interventions used active forms of clinician education (workshops, supplemented in one study by consensus-building sessions) combined with audit and feedback. The results were mixed. One intervention ^146^ was associated with a 13% increase in the percentage of antibiotic prescriptions for short-course regimens in the intervention group compared with the comparison group; the second study ^147^ found that the intervention had little effect on antibiotic duration (relative increase of antibiotic duration 0.06 days), while the third ^154^ documented a relative decrease in defined daily doses equivalent to a reduction of 1.89 days in antibiotic duration in the intervention compared with comparison group. Using a similar calculation of defined daily doses per prescription, an intervention using only audit and feedback found a relative decrease in antibiotic duration of 0.55 days in the intervention group compared with the comparison group. ^151^

### Studies Not Eligible for Median Effect Size Analysis

Eleven trials in six studies ^135,^ ^136,^ ^139,^ ^146,^ ^148,^ ^152^ met inclusion criteria for this review but did not present data amenable for inclusion in the median effects analyses. The majority of these (seven trials from three studies) ^135,^ ^148,^ ^152^ targeted antibiotic selection in general, while three trials (from two studies) ^136,^ ^146^ focused on UTIs and one on ARIs. ^139^ The methodologic quality of these interventions was generally similar to those that were included in the median effects analysis: among 11 trials, four (from three studies) ^135,^ ^139,^ ^146^ used randomized controlled designs, but all non-randomized trials used a comparable comparison group and adequately described the rationale for its selection. However, none of the trials measured prescribing by chart review.

The majority of these interventions evaluated the effect of clinician educational outreach alone or in combination with other QI strategies. One study ^152^ evaluated the effects of outreach performed by a physician or pharmacist on prescribing of contraindicated antibiotics (antibiotics deemed unsafe for routine office use) and of oral cephalosporins. Both types of interventions were compared to a comparison group that received either no intervention or a passive mailed intervention (which had no effect relative to the no intervention group). Outreach performed by a physician achieved relative reductions of 85% and 50% in the number of prescriptions per patient over a 1-year period for oral cephalosporins and contraindicated antibiotics, respectively, compared with 67% and 35% reductions by the pharmacist-educator and 41% and 33% reductions in the comparison group. (Data on absolute reductions were not presented.)

Another study comprising two interventions found that educational outreach reduced non-recommended antibiotic prescribing 31% relative to the comparison group, compared with a relative reduction of 10% in physicians receiving only printed materials. Both of these relative reductions were in part attributable to a 12% increase in non-recommended antibiotic use in the comparison group over the study period. ^135^

Other interventions employed variations on the classic approach to educational outreach. One study using pharmaceutical sales representatives to promote amoxicillin use for children with otitis media documented a non-significant 1.4% increase in adjusted market share for this drug in regions receiving outreach compared with control regions. ^139^ Finally, another study evaluated two multifaceted interventions that included feedback delivered via distribution of a workbook or educational outreach. These investigators found a 0% and 12% improvement in the workbook and educational outreach groups (respectively) compared with the comparison group, based on an outcome of mean percent change in recommended antibiotic prescribing per 1000 patients over a 3-month period. ^136^

One study used an interrupted time series design to evaluate financial and regulatory incentives designed to reduce fluoroquinolone prescribing to elderly patients in a Canadian province. After implementation, use of this drug class fell from 20.2% to 4.2% of all antibiotic drug claims registered with the province's prescription drug insurance plan. ^148^

### Comparisons Within Studies

Five studies evaluated two or more separate interventions; three of these studies ^135,^ ^136,^ ^152^ are described in the section above, and the remainder are described below. One study documented a 5.1% improvement in recommended antibiotic prescribing by physicians invited to lectures sponsored by a local department of clinical microbiology, compared with a 1.1% improvement in physicians invited to similar lectures sponsored by a pharmaceutical company; the control group and both intervention groups all received written materials. ^141^ The other study compared antibiotic prescribing for pediatric otitis media among three small sites of a health maintenance organization, where one site developed and implemented a consensus guideline for treatment of this condition, the second site implemented this guideline through meetings and written materials, and the third site served as control. ^137^ Guideline-concordant prescribing improved 13.0% at the development site and 0.1% at the implementation site, and fell 22.6% at the control site. Of note, baseline concordance was substantially lower at the development site (64.3%) than at the other two sites (87.8% and 89.6%).

As noted above, nine trials (from five studies) ^121,^ ^138,^ ^141,^ ^152,^ ^153^ provided some form of lower-intensity activity in a comparison group that was considered in the study to be a control arm; five of these (from four studies) ^121,^ ^138,^ ^141,^ ^153^ presented data suitable for median effects analysis. These five trials were a heterogeneous group, including one intervention comparing educational outreach to a comparison group receiving low-intensity feedback (with 8.4% relative improvement in the intervention arm relative to control), ^138^ one comparing antibiotic workshops to a comparison group receiving microbiology tutorials (2.5% relative improvement in the intervention arm), ^121^ one comparing mailed audit and feedback to distribution of written materials (2% relative superiority in the intervention arm), ^153^ and two interventions from one study comparing meetings to distribution of written materials (5.1% and 1.1% relative improvement in the intervention arms). ^141,^ ^153^ Overall, the median effect size of interventions whose efficacy was compared with that of a low-intensity control was lower than those whose comparison group received no form of activity (median effect 3.1% vs 14.4%, P=0.04; Table 5 ).

Among these studies, there were nine comparisons of active vs. passive provider education (either as distinct intervention arms, or as an intervention arm and low-intensity intervention control arm). In all nine, the active form of education resulted in greater improvement than the passive one. ^121,^ ^135^ – ^138,^ ^152^

### Special Populations and Secondary Endpoints

The median effect of trials focusing on ARIs and UTIs was identical (12%), with similar median effects across different types of interventions. Three studies enrolled children ^102,^ ^137,^ ^139^ (one of which ^137^ focused specifically on children enrolled in an HMO); the median effect of interventions in these studies was similar to the overall effect of non-age-targeted studies. Two studies enrolled the elderly ^143,^ ^148^ ; the first achieved a 4.3% improvement over control using a combination of passive clinician education with audit and feedback (similar to the median effect for all studies in this category), ^143^ while the second (an interrupted time series) documented a 16% absolute reduction in fluoroquinolone use after implementation of financial and regulatory incentives. ^148^

No studies looked at clinical outcomes, including adverse drug reactions, clinical status, or health services utilization. Similarly, no studies evaluated the effect of interventions on antimicrobial resistance, or visit duration. A single study ^140^ that evaluated clinician attitudes documented a mean response of 4.0 (on a 5-point Likert scale, 5=“strongly agree” and 1=“strongly disagree”) regarding clinicians' opinions of the intervention as an appropriate mechanism to optimize medication use.

Four studies looked at cost outcomes, ^121,^ ^140,^ ^143,^ ^144^ of which three presented data in usable form. Each of these three interventions decreased cost by approximately 20–30%. One study using clinician education and audit and feedback documented a median $3.37 (31%) increase in the mean cost of an antibiotic prescription in the comparison group, compared with no change in costs in the intervention group. ^143^ Two studies evaluated the total cost of antimicrobials in a health care system, with one ^144^ finding an 18% relative decrease in total antimicrobial costs attributable to non-recommended antibiotics in the intervention group compared to the comparison group, and the other a 9% rise in total antibiotic costs in the comparison group, compared with a 10% decrease in the intervention arm. ^121^