# Technical Expert Panel and Peer Reviewers

Technical Expert Panel

Jeremy Grimshaw, MBChB, PhD, University of Ottawa, Cochrane Collaboration Effective Practice and Organisation of Care Group (EPOC)

Andrew Oxman, MD, MSc, Department of Health Services Research, Norwegian Directorate for Health and Social Welfare, EPOC

Russell Glasgow, PhD, Kaiser Permanente, Colorado

Martin Eccles, MD, Centre for Health Services Research, University of Newcastle upon Tyne, EPOC

Harmon Jordan, ScD, previously with New England Medical Center Evidence-based Practice Center, currently at Abt Associates

Val Lawrence, MD, MSc, The University of Texas Health Science Center at San Antonio and South Texas Veterans Health Care System

James Zazzali, PhD, RAND Charles Homer, MD, MPH, National Institute for Children's Health Care Quality

Peer Reviewers

Richard Besser, MD, Medical Epidemiologist, Centers for Disease Control and Prevention

Edward Belongia, MD, Epidemiology, Marshfield Clinic

Jonathan Finkelstein, MD, MPH, Department of Ambulatory Care and Prevention, Harvard Medical School

Kitty Corbett, PhD, Anthropologist, Denver University

Randall Stafford, MD, PhD, Stanford University

Brian Strom, MD, MPH, CERT Program, University of Pennsylvania

Theoklis Zaoutis, MD, Department of Pediatrics, University of Pennsylvania School of Medicine