# Random Effects Meta-Analysis of Included Trials

## A. Methods

For our initial analytic approach, we identified studies that supplied information on the post-intervention rate of antibiotic use in both intervention and control groups. The primary outcomes were the same as used in the main report (for treatment articles, the percentage of visits at which an antibiotic was prescribed; for selection articles, the percentage of patients receiving a recommended antibiotic or the percentage compliance with a clinical guideline for antibiotic prescribing). We used the pooled risk difference as the summary statistic; the risk difference for each individual study was equal to (intervention _ post _ - control _ post _ ). Thus, for the treatment articles, the risk difference indicates the reduction in antibiotic prescribing in the intervention group compared to control. In the selection articles, the risk difference indicates the improvement in prescribing of a recommended antibiotic in the intervention group compared to control. We performed meta-analysis using the random effects model of DerSimonian and Laird on these data. In order to be suitable for meta-analysis, included studies were required to report the number of patients in each group (intervention and control). Analyses were performed using Stata version 8.2 (Stata Corp. College Station, TX).

## B. Results

Antibiotic treatment decision studies. Twenty-one articles reporting a total of 26 comparisons met the inclusion criteria. The pooled risk difference across all studies was -13.8% (95% CI -17.7% to -9.9%,) indicating a significant reduction in antibiotic prescribing, as illustrated in the Figure below. However, significant heterogeneity was present, with the chi-squared test of heterogeneity significant at p < 0.001. The I^2^ value, which indicates the percentage of the variance in the risk difference attributable to heterogeneity, was 96.2%.

We performed stratified analyses to investigate potential sources of heterogeneity. Having identified delayed prescribing studies as a unique subset of interventions, we repeated the analyses without these studies. The results continued to show a statistically significant reduction in prescribing (pooled RD -9.6%, 95% CI -12.6% to -6.9%,) but the tests of heterogeneity remained significant (p<0.001 for chi-squared test, I^2^ 92.9%). We found consistent evidence for high levels of heterogeneity when analyses were further restricted to randomized controlled trials (p<0.001, I^2^ 86.4%), interventions targeting ARIs only (p<0.001, I^2^ 93.8%), or studies with baseline prescribing rates above the median (p<0.001, I^2^ 92.3%) or below the median (p<0.001, I^2^ 97.1%). Heterogeneity was present for studies using each specific QI strategy as well, with p<0.001 for all individual QI strategies and combinations of strategies.

Heterogeneity may always be present in a meta-analysis, and finding heterogeneity generally warrants a search for potential sources of heterogeneity via stratified analyses. However, we recognize that pooling studies of quality improvement strategies of necessity involves combining studies across a broad range of target populations, target conditions, baseline care practices, and interventions. Although we selected articles reporting a common outcome, the outcome itself may have been measured in different ways (e.g., direct measurement of prescribing by chart review, versus measurement of actual antibiotic use by patient interview or pharmacy records).

Antibiotic selection decision studies. For the selection decision studies, an additional potential complication was induced by combining articles with an explicit clinical guideline for prescribing and those with recommendations but no defined guideline. Thus, we did not feel that stratified analyses alone could identify any factors responsible for heterogeneity, and this was borne out by the results in stratified analyses of the treatment studies.

Based on these results, we did not feel that performing random-effects meta-analysis would be appropriate for either the treatment studies or the selection studies, and opted to use the median effects approach as described in the Methods section.

Forest plot showing risk differences for treatment studies by random effects meta-analysis

Figure Legend

Forest plot for the risk difference for antibiotic prescribing in intervention groups post-intervention as compared with comparison groups post-intervention. Negative numbers indicate reductions in antibiotic use.