# EPOC and Medline Search for Antibiotic QI Articles

We conducted two searches to identify relevant articles.

1. EPOC Databases Search: The EPOC, Medline and HealthSTAR search strategy (see below) was combined with the antiobiotic terms search strategy (see below) to identify relevant articles from the EPOC databases upto October 2004.

2. Medline Search: To identify more recent articles that may not have been indexed in the EPOC databases, we searched Medline from June 2004 to November 2004 using the search below.

## 1. EPOC Databases Search

[underlined: EPOC MEDLINE and HealthSTAR * Search Strategy]

*insert:

(randomised or randomized).tw.

(random$ adj1 (allocat$ or assign$)).tw.

1 exp * education, continuing/
2 (education$ adj2 (program$ or intervention? or meeting? or session? or strateg$ or workshop? or visit?)).tw.
3 (behavio?r$ adj2 intervention?).tw.
4 * pamphlets/
5 (leaflet? or booklet? or poster or posters).tw.
6 ((written or printed or oral) adj information).tw.
7 (information$ adj2 campaign).tw.
8 (education$ adj1 (method? or material?)).tw.
9 * advance directives/
10 outreach.tw.
11 ((opinion or education$ or influential) adj1 leader?).tw.
12 facilitator?.tw.
13 academic detailing.tw.
14 consensus conference?.tw.
15 * guideline adherence/
16 practice guideline?.tw.
17 (guideline? adj2 (introduc$ or issu$ or impact or effect? or disseminat$ or distribut$)).tw.
18 ((effect? or impact or evaluat$ or introduc$ or compar$) adj2 training program$).tw.
19 * reminder systems/
20 reminder?.tw.
21 (recall adj2 system$).tw.
22 (prompter? or prompting).tw.
23 algorithm?.tw.
24 * feedback/ or feedback.tw.
25 (feedback adj1 (loop? or control? or regula$ or mechanism? or inhib$ or system? or circuit? or sensory or visual or audio$ or auditory)).tw.
26 23 not 24
27 chart review$.tw.
28 ((effect? or impact or records or chart?) adj2 audit).tw.
29 compliance.tw.
30 marketing.tw.
31 or/1–22, 26–30
32 exp * reimbursement mechanisms/
33 fee for service.tw.
34 * capitation fee/
35 * “deductibles and coinsurance”/
36 cost shar$.tw.
37 (copayment? or co payment?).tw.
38 (prepay$ or prepaid or prospective payment?).tw.
39 * hospital charges/
40 formular$.tw.
41 fundhold$.tw.
42 * medicaid/
43 * medicare/
44 blue cross.tw.
45 or/32–44
46 * nurse clinicians/
47 * nurse midwives/
48 * nurse practitioners/
49 (nurse adj (rehabilitator? or clinician? or practitioner? or midwi$)).tw.
50 * pharmacists/
51 clinical pharmacist?.tw.
52 paramedic?.tw.
53 * patient care team/
54 exp * patient care planning/
55 (team? adj2 (care or treatment or assessment or consultation)).tw.
56 (integrat$ adj2 (care or service?)).tw.
57 (care adj2 (coordinat$ or program$ or continuity)).tw.
58 (case adj1 management).tw.
59 exp * ambulatory care facilities/
60 * ambulatory care/
61 or/46–60
62 * home care services/
63 * hospices/
64 * nursing homes/
65 * office visits/
66 * house calls/
67 * day care/
68 * aftercare/
69 * community health nursing/
70 (chang$ adj1 location?).tw.
71 domiciliary.tw.
72 (home adj1 treat$).tw.
73 day surgery.tw.
74 * medical records/
75 * medical records systems, computerized/
76 (information adj2 (management or system?)).tw.
77 * peer review/
78 * utilization review/
79 exp * health services misuse/
80 or/62–79
81 * physician's practice patterns/
82 quality assurance.tw.
83 * process assessment/ [health care]
84 * program evaluation/
85 * length of stay/
86 (early adj1 discharg$).tw.
87 discharge planning.tw.
88 offset.tw.
89 triage.tw.
90 exp * referral/ and consultation/
91 * drug therapy, computer assisted/
92 near patient testing.tw.
93 * medical history taking/
94 * telephone/
95 (physician patient adj (interaction? or relationship?)).tw.
96 * health maintenance organizations/
97 managed care.tw.
98 (hospital? adj1 merg$).tw.
99 or/81–98
100 ((standard or usual or routine or regular or traditional or conventional or pattern) adj2 care).tw.
101 (program$ adj2 (reduc$ or increas$ or decreas$ or chang$ or improv$ or modify$ or monitor$ or care)).tw.
102 (program$ adj1 (health or care or intervention?)).tw.
103 ((effect? or impact or evaluat$ or introduc$ or compar$) adj2 treatment program$).tw.
104 ((effect? or impact or evaluat$ or introduc$ or compar$) adj2 care program$).tw.
105 ((effect? or impact or evaluat$ or introduc$ or compar$) adj2 screening program$).tw.
106 ((effect? or impact or evaluat$ or introduc$ or compara$) adj2 prevent$ program$).tw.
107 (computer$ adj2 (dosage or dosing or diagnosis or therapy or decision?)).tw.
108 ((introduc$ or impact or effect? or implement$ or computer$) adj2 protocol?).tw.
109 ((effect? or impact or introduc$) adj2 (legislation or regulations or policy)).tw.
110 or/100–109
111 31 or 45 or 61 or 80 or 99 or 110
112 randomized controlled trial.pt.
113 controlled clinical trial.pt.
114 intervention studies/
115 experiment$.tw.
116 (time adj series).tw.
117 (pre test or pretest or (posttest or post test)).tw.
118 random allocation/
119 impact.tw.
120 intervention?.tw.
121 chang$.tw.
122 evaluation studies/
123 evaluat$.tw.
124 effect?.tw.
125 comparative studies/
126 animal/
127 human/
128 126 not 127
129 or/112–125
130 129 not 128
131 111 and 130

[underlined: Antibiotics Terms Search Strategy]

- antibiotic *
- Amoxicillin
- Azithromycin
- Cephalosporin *
- Cephalexin
- Ciprofloxacin
- Clarithromycin
- Clindamycin
- Doxycycline
- Erythromycin
- Flouroquinolone *
- Fluconazole
- Levofloxacin
- Macrolide *
- Metronidazole
- Nitrofurantoin
- Penicillin
- Tetracycline
- Trimethoprim

## 2. Medline Search

#1 Targets clinical conditions | “Community-Acquired Infections”[MeSH] OR “Respiratory Tract Infections”[MeSH] OR “Bronchitis”[MeSH] OR “Pneumonia, Bacterial”[MeSH] OR Sinusitis[MeSH] OR Common Cold[MeSH] OR Influenza[MeSH] OR “Urinary Tract Infections”[MeSH] OR Sexually Transmitted Diseases[MeSH] OR Vaginitis[MeSH] OR Candidiasis, Vulvovaginal[MeSH] OR Pelvic Inflammatory Disease[MeSH] | 365549
#2 Targets antibiotics and prescribing | Anti-Bacterial Agents[MeSH] OR Antibiotic[ti] OR Anti-Infective Agents, Urinary[MeSH] OR Antibiotics[ti] OR Prescriptions, Drug[MeSH] OR Drug Utilization[MeSH] OR Physician's Practice Patterns[MeSH] OR Attitude of Health Personnel [MeSH] OR Prescribing[ti] OR Prescription[ti] | 255351
#3 Targets QI strategies that tend to be multi-factorial using relevant MeSH terms and title words | Disease Management [mh] OR Patient Care Planning [mh] OR Patient-Centered Care [mh] OR Primary Health Care [mh] OR Progressive Patient Care [mh] OR Critical Pathways [mh] OR Delivery of Health Care, Integrated [mh] OR Health Services Accessibility [mh] OR Managed Care Programs [mh] OR Product Line Management [mh] OR Patient Care Team [mh] OR Patient-Centered Care [mh] OR Behavior Control [mh] OR Counseling [mh] OR Health Promotion [mh] OR Patient Compliance [mh] OR After-Hours Care [mh] OR ((coordination [ti] OR coordinated [ti] OR Multifactorial [ti] OR Multi-factorial [ti] OR Multicomponent [ti] OR Multi-component [ti] OR multidisciplinary [ti] OR multi-disciplinary [ti] OR interdisciplinary [ti] OR inter-disciplinary [ti] OR integrated [ti] OR community-based [ti] OR organized [ti]) AND (care [ti] OR approach [ti] OR intervention [ti] OR strategy [ti] OR strategies [ti] OR management [ti] OR managing [ti] OR center* [ti] OR clinic*[ti])) OR Organization and Administration [mh] | 735481
#4 Targets TQM and CQI | Total Quality Management [mh] OR Quality control [mh] OR TQM [ti] OR CQI [ti] OR (quality [ti] AND (continuous [ti] OR total [ti]) AND (management [ti] OR improvement [ti])) | 31249
#5 Targets provider education | Education, Continuing [mh] OR (Education [ti] AND Continuing [ti] AND (medical [ti] OR professional* [ti] OR nursing [ti] OR physician* [ti] OR nurse* [ti])) OR (outreach [ti] AND (visit*[ti] OR educational [ti]) OR (academic [ti] AND detailing [ti])) | 36,929
#6 Targets diffusion of innovation | Diffusion of Innovation [mh] OR (Diffusion [ti] AND (Innovation [ti] OR technology [ti])) | 5519
#7 Targets audit and feedback, reminder systems, and financial incentives | Medical audit [mh] OR ((Audit [ti] OR feedback [ti] OR compliance [ti] OR adherence [ti] OR training [ti]) AND (improvement* [ti] OR improving [ti] OR improves [ti] OR improve [ti] OR guideline* [ti] OR practice* [ti] OR medical [ti] OR provider* [ti] OR physician* [ti] OR nurse* [ti] OR clinician* [ti] OR practice guidelines [mh] OR academic [ti] OR visit* [ti])) OR Reminder Systems [mh] OR Reminder* [ti] OR ((financial [ti] OR economic [ti] OR physician* [ti] OR patient*) AND incentive* [ti]) OR Reimbursement Mechanisms [mh] | 40,152
#8 Targets informatics and telemedicine | Medical Informatics [mh] OR computer [ti] OR (decision [ti] AND support [ti]) OR Telemedicine[mh] OR Telemedicine [ti] OR telecommunication* [ti] OR Internet [mh] OR web [ti] OR modem [ti] OR telephone* [ti] OR telephone [mh] | 339608
#9 Overall set of articles relating to QI | #3 OR #4 OR #5 OR #6 OR #7 OR #8 | 1072468
#10 Combines QI strategies search terms with ABX search | #9 AND (#1 OR #2) | 75,957
#11 Systematic review search string | (meta-analysis [pt] OR meta-analysis [tw] OR metanalysis [tw]) OR ((review [pt] OR guideline [pt] OR consensus [ti] OR guideline* [ti] OR literature [ti] OR overview [ti] OR review [ti] OR Decision Support Techniques [mh]) AND ((Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw])) OR (handsearch* [tw] OR search* [tw] OR searching [tw]) AND (hand [tw] OR manual [tw] OR electronic [tw] OR bibliographi* [tw] OR database* OR (Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw]))))) OR ((synthesis [ti] OR overview [ti] OR review [ti] OR survey [ti]) AND (systematic [ti] OR critical [ti] OR methodologic [ti] OR quantitative [ti] OR qualitative [ti] OR literature [ti] OR evidence [ti] OR evidence-based [ti]))) BUTNOT (case reports [pt] OR case* [ti] OR report [ti] OR editorial [pt] OR comment [pt] OR letter [pt] | 46,865
#12 Original research search string | Randomised [ti] OR Randomized [ti] OR Controlled [ti] OR intervention [ti] OR evaluation [ti] OR impact [ti] OR effectiveness [ti] OR Evaluation [ti] OR Studies [ti] OR study [ti] Comparative [ti] OR Feasibility [ti] OR Program [ti] OR Design [ti] OR Clinical Trial [pt] OR Randomized Controlled Trial [pt] OR Epidemiologic Studies [mh] OR Evaluation Studies [mh] OR Comparative Study [mh] OR Feasibility Studies [mh] OR Intervention Studies [mh] OR Program Evaluation [mh] OR Epidemiologic Research Design [mh] | 2394801
#13 Subset of #10 likely to include original research or systematic reviews | #10 AND (#11 OR #12) | 21,936
#14 Supplementary search results | [See supplement below] | 25,569
#15 | #13 OR #14 | 42317
#16 | #15 BUTNOT (editorial [pt] OR comment [pt] OR letter [pt] OR news [pt] OR newspaper article [pt] OR case reports[pt]) | 36850
#17 | #14 limit to Human and English | 31200
#18 | #15 limit to June 2004 – November 2004 | 846

Supplemental search:

#1 | (Drug Therapy [mh] OR Drug Utilization [mh] OR Drug Utilization Review [mh] OR Drug Therapy, Combination [mh] OR Decision Support Techniques [mh] OR Drug Information Services [mh] OR Decision Making [mh] OR Attitude of Health Personnel [mh] OR Attitude to Health [mh] OR Clinical Competence [mh] OR Education, Continuing [mh] OR Education, Medical, Continuing [mh] OR Guideline Adherence [mh] OR Practice Guidelines [mh] OR guideline [ti] OR Health Education [mh] OR “Health Knowledge, Attitudes, Practice” [mh] OR Health Personnel [mh] OR Health Promotion [mh] OR Health Services Misuse [mh] OR Medical Audit [mh] OR Models, Educational [mh] OR Counseling [mh] OR Patient Education [mh] OR Patient Participation [mh] OR Patient Satisfaction [mh] OR Physician-Patient Relations [mh] OR Physician's Practice Patterns [mh] OR Point-of-Care Systems [mh] OR Prescribing [ti] OR Prescription* [ti] OR Prescriptions, Drug [mh]) | 887970
#2 | (Anti-Infective Agents [mh] OR Drug Resistance, Microbial [mh] OR Disease Transmission [mh] OR Infection/ drug therapy [mh] OR antibiotic* [ab] OR antimicrobial* [ab] OR anti-infective [ab] OR Cephalexin [ab] OR Cephalosporin* [ab] OR Chloramphenicol [ab] OR Clindamycin [ab] OR Cephalexin [mh] OR Cephalosporin* [mh] OR Chloramphenicol [mh] OR Clindamycin [mh] Common Cold/ drug therapy [mh] OR Community-Acquired Infections/drug therapy [mh] OR Cough/drug therapy [mh] OR Cystitis/drug therapy [mh] OR Diarrhea/drug therapy [mh] OR Diarrhea/chemically induced [mh] OR Erythromycin [ab] OR Erythromycin [mh] OR Fluoroquinolone* [ab] OR Fluoroquinolone* [mh] OR Otitis Media/ drug therapy [mh] OR Penicillin* [mh] OR penicillin* [ab] OR Pharyngitis [mh] OR Pneumococcal Infections [mh] OR Respiratory Tract Infections [mh] OR Rhinitis [mh] OR Streptococcal Infections [mh] OR Streptococcus [ab] OR Tetracycline [ab] OR Tonsillitis [mh] OR Trimethoprim [ab] OR Tetracycline [mh] OR Trimethoprim [mh] OR Urinary Tract Infections [mh] OR Virus Diseases [mh] OR Anti-Infective [ti] OR Antiinfective [ti] OR antibiotic* [ti] OR antimicrobial* [ti] OR Cephalosporin* [ti] OR Chloramphenicol [ti] OR Clindamycin [ti] OR infection* [ti] OR Cystitis [ti] OR Diarrhea [ti] OR Erythromycin [ti] OR macrolide* [ti] OR Fluoroquinolone* [ti] OR “Otitis Media” [ti] OR Pharyngitis [ti] OR throat [ti] OR cough [ti] OR Pneumococcal [ti] OR “Respiratory Tract” [ti] OR Streptococcal [ti] OR Tetracycline [ti] OR Tonsillitis [ti] OR Trimethoprim [ti]) | 948535
#3 | #1 AND #2 | 73845
#4 | (systematic [sb] OR Randomised [ti] OR Randomized [ti] OR Controlled [ti] OR intervention [ti] OR evaluation [ti] OR impact [ti] OR effectiveness [ti] OR Evaluation [ti] OR Studies [ti] OR study [ti] Comparative [ti] OR Feasibility [ti] OR Program [ti] OR Design [ti] OR Clinical Trial [pt] OR Randomized Controlled Trial [pt] OR Epidemiologic Studies [mh] OR Evaluation Studies [mh] OR Comparative Study [mh] OR Feasibility Studies [mh] OR Intervention Studies [mh] OR Program Evaluation [mh] OR Epidemiologic Research Design [mh]) | 2394833
#5 | #3 AND #4 | 25,569