# Appendixes

Appendix A Summary of Key Studies

Appendix B Summaries of Included Studies, Grouped by Setting and Measured Population

Appendix C EPOC and Medline Search for Antibiotic QI Articles

Appendix D Antibiotic Abstraction Forms for Screening and Full-Text Review

Appendix E Random Effects Meta-Analysis of Included Trials

Appendix F Technical Expert Panel and Peer Reviewers