# Tables

Table 1. Included studies.

Table 2a. Quality improvement strategies.

Table 2b. Quality improvement sub-strategies.

Table 3. Number of different quality improvement strategies included in articles.

Table 4. Quality improvement strategy combinations.

Table 5. Screening studies.

Table 6a. Effect of quality improvement strategies on blood pressure outcomes*.

Table 6b. Effect of quality improvement strategies on summary adherence outcomes.

Table 7a. Effect of number of quality improvement strategies on blood pressure outcomes.

Table 7b. Effect of number of quality improvement strategies on summary adherence outcomes.

Table 8a. Effect of specific quality improvement sub-strategies on blood pressure outcomes.

Table 8b. Effect of specific quality improvement sub-strategies on summary adherence outcomes.

Table 9a. Effect of information systems on blood pressure outcomes*.

Table 9b. Effect of information systems on summary adherence outcomes*.

Table 10a. Association of methodologic features* with decreased blood pressures.

Table 10b. Association of methodologic features* with increased percentage of patients in blood pressure target range.

Table 10c. Association of methodologic features* with summary adherence outcomes.

Table 11. Comparison of study design by quality improvement strategy on blood pressure outcomes.

Table 12a. Association of study size with systolic blood pressure outcomes.

Table 12b. Association of study size with diastolic blood pressure outcomes.

## Table References

Note: Some articles are listed more than once because they report multiple comparisons. Article records were repeated and data for each comparison were abstracted into separate files. These references are noted as an “additional comparison.”

1 Mortality after 10 1/2 years for hypertensive participants in the Multiple Risk Factor Intervention Trial. Circulation 1990;82(5):1616–28.
2 Aubin M, Vezina L, Fortin JP, et al. Effectiveness of a program to improve hypertension screening in primary care. CMAJ. 1994;150(4):509-15. [pmid: 8313262]. [pmcid: 1486287].
3 Aucott JN, Pelecanos E, Dombrowski R, et al. Implementation of local guidelines for cost-effective management of hypertension. A trial of the firm system. Journal of General Internal Medicine. 1996;11(3):139-46. [pmid: 8667090].
4 Avanzini F, Corsetti A, Maglione T, et al. Simple, shared guidelines raise the quality of antihypertensive treatment in routine care. American Heart Journal 2002;Online. 144(4):726–32.
5 Barnett GO, Winickoff RN, Morgan MM, et al. A computer-based monitoring system for follow-up of elevated blood pressure. Med Care. 1983;21(4):400-09. [pmid: 6341724].
6 Bass MJ, McWhinney IR, Donner A. Do family physicians need medical assistants to detect and manage hypertension?. CMAJ. 1986;134(11):1247-55. [pmid: 2871915]. [pmcid: 1491080].
7 Becker LA, Glanz K, Sobel E, et al. A randomized trial of special packaging of antihypertensive medications. J Fam Pract. 1986;22(4):357-61. [pmid: 3958683].
8 Blenkinsopp A, Phelan M, Bourne J, et al. Extended adherence support by community pharmacists for patients with hypertension: A randomised controlled trial. International Journal of Pharmacy Practice. 2000;8(3):165-75.
9 Bogden PE, Abbott RD, Williamson P, et al. Comparing standard care with a physician and pharmacist team approach for uncontrolled hypertension. J Gen Intern Med. 1998;13(11):740-5. [pmid: 9824519]. [pmcid: 1497023].
10 Borenstein JE, Graber G, Saltiel E, et al. Physician-pharmacist comanagement of hypertension: a randomized, comparative trial. Pharmacotherapy. 2003;23(2):209-16. [pmid: 12587810].
11 Brook RH, Ware JE Jr, Rogers WH, et al. Does free care improve adults' health?. New England Journal of Medicine. 1983;309(23):1426-34. [pmid: 6355851].
12 Campbell NC, Ritchie LD, Thain J, et al. Secondary prevention in coronary heart disease: a randomised trial of nurse led clinics in primary care. Heart. 1998;80(5):447-52. [pmid: 9930042]. [pmcid: 1728827].
13 Carter BL, Barnette DJ, Chrischilles E, et al. Evaluation of hypertensive patients after care provided by community pharmacists in a rural setting. Pharmacotherapy. 1997;17(6):1274-85. [pmid: 9399611].
14 Curzio JL, Rubin PC, Kennedy SS, et al. A comparison of the management of hypertensive patients by nurse practitioners compared with conventional hospital care. J Hum Hypertens. 1990;4(6):665-70. [pmid: 2096208].
15 Earp JA, Ory MG, Strogatz DS. The effects of family involvement and practitioner home visits on the control of hypertension. Am J Public Health. 1982;72(10):1146-54. [pmid: 7114339]. [pmcid: 1650178].
16 Erfurt JC, Foote A, Heirich MA. Worksite wellness programs: incremental comparison of screening and referral alone, health education, follow-up counseling, and plant organization. Am J Health Promot. 1991;5(6):438-48. [pmid: 10148672].
17 Erickson SR, Slaughter R, Halapy H. Pharmacists' ability to influence outcomes of hypertension therapy. Pharmacotherapy. 1997;17(1):140-7. [pmid: 9017775].
18 Evans CE, Haynes RB, Birkett NJ, et al. Does a mailed continuing education program improve physician performance? Results of a randomized trial in antihypertensive care. JAMA. 1986;255(4):501-4. [pmid: 3941533].
19 Foote A, Erfurt JC. Hypertension control at the work site. Comparison of screening and referral alone, referral and follow-up, and on-site treatment. N Engl J Med. 1983;308(14):809-13. [pmid: 6835271].
20 Forstrom MJ, Ried LD, Stergachis AS, et al. Effect of a clinical pharmacist program on the cost of hypertension treatment in an HMO family practice clinic. DICP. 1990;24(3):304-9. [pmid: 2316237].
21 Fortmann SP, Winkleby MA, Flora JA, et al. Effect of long-term community health education on blood pressure and hypertension control. The Stanford Five-City Project. American Journal of Epidemiology. 1990;132(4):629-46. [pmid: 2403104].
22 Friedman RH, Kazis LE, Jette A, et al. A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control. Am J Hypertens. 1996;9(4 Pt 1):285-92. [pmid: 8722429].
23 Garcao JA, Cabrita J. Evaluation of a pharmaceutical care program for hypertensive patients in rural Portugal. J Am Pharm Assoc (Wash). 2002;42(6):858-64. [pmid: 12482009].
24 Garcia-Pena C, Thorogood M, Armstrong B, et al. Pragmatic randomized trial of home visits by a nurse to elderly people with hypertension in Mexico. Int J Epidemiol. 2001;30(6):1485-91. [pmid: 11821367].
25 Goldberg HI, Wagner EH, Fihn SD, et al. A randomized controlled trial of CQI teams and academic detailing: Can they alter compliance with guidelines?. Jt Comm J Qual Improv. 1998;24(3):130-42. [pmid: 9568553].
26 Gullion DS, Tschann JM, Adamson TE, et al. Management of hypertension in private practices: A randomized controlled trial in continuing medical education. J Contin Educ Health Prof. 1988;8:239-55.
27 Hetlevik I, Holmen J, Kruger O. Implementing clinical guidelines in the treatment of hypertension in general practice. Evaluation of patient outcome related to implementation of a computer-based clinical decision support system. Scand J Prim Health Care. 1999;17(1):35-40. [pmid: 10229991].
28 Hill MN, Bone LR, Hilton SC, et al. A clinical trial to improve high blood pressure care in young urban black men: Recruitment, follow-up, and outcomes. Am J Hypertens. 1999;12(6):548-54. [pmid: 10371363].
29 Hla KM, Feussner JR, Blessing-Feussner CL, et al. BP control. Improvement in a university medical clinic by use of a physician's associate. Arch Intern Med. 1983;143(5):920-3. [pmid: 6148049].
30 Solomon DK. Clinical and economic outcomes in the hypertension and COPD arms of a multicemeter outcomes study. J Am Pharm Assoc. 1998;38:574-85.
31 Jennett PA, Wilson TW, Hayton RC, et al. Desirable behaviours in the office management of hypertension addressed through continuing medical education. Can J Public Health. 1989;80(5):359-62. [pmid: 2804866].
32 Jewell D, Hope J. Evaluation of a nurse-run hypertension clinic in general practice. Practitioner. 1988;232(1447):484-87. [pmid: 3249732].
33 Kogan JR, Reynolds EE, Shea JA. Effectiveness of report cards based on chart audits of residents' adherence to practice guidelines on practice performance: A randomized controlled trial. Teach Learn Med. 2003;15(1):25-30. [pmid: 12632705].
34 Logan AG, Milne BJ, Achber C, et al. Cost-effectiveness of a worksite hypertension treatment program. Hypertension. 1981;3(2):211-18. [pmid: 6783519].
35 Logan AG, Milne BJ, Flanagan PT, et al. Clinical effectiveness and cost-effectiveness of monitoring blood pressure of hypertensive employees at work. Hypertension. 1983;5(6):828-36. [pmid: 6418647].
36 Markov KV, Smirnov YV. Prospective epidemiological study of arterial hypertension under preventive measures. Cor Vasa. 1986;28(3):161-6. [pmid: 3743085].
37 McAlister NH, Covvey HD, Tong C, et al. Randomised controlled trial of computer assisted management of hypertension in primary care. BMJ (Clin Res Ed). 1986;293(6548):670-4.
38 McClellan WM, Craxton LC. Improved follow-up care of hypertensive patients by a nurse practitioner in a rural clinic. J Rural Health. 1985;1(2):34-41. [pmid: 10279389].
39 McDowell I, Newell C, Rosser W. A randomized trial of computerized reminders for blood pressure screening in primary care. Med Care. 1989;27(3):297-305. [pmid: 2494397].
40 McGhee SM, McInnes GT, Hedley AJ, et al. Coordinating and standardizing long-term care: Evaluation of the west of Scotland shared-care scheme for hypertension. British Journal of General Practice. 1994;44(387):441-45. [pmid: 7748631]. [pmcid: 1239016].
41 Mehos BM, Saseen JJ, MacLaughlin EJ. Effect of pharmacist intervention and initiation of home blood pressure monitoring in patients with uncontrolled hypertension. Pharmacotherapy. 2000;20(11):1384-9. [pmid: 11079287].
42 Midanik LT, Resnick B, Hurley LB, et al. Home blood pressure monitoring for mild hypertensives. Public Health Rep. 1991;106(1):85-9. [pmid: 1899945]. [pmcid: 1580210].
43 Montgomery AA, Fahey T, Peters TJ, et al. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: Randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578]. [pmcid: 27312].
44 Nilsson G, Hjemdahl P, Hassler A, et al. Feedback on prescribing rate combined with problem-oriented pharmacotherapy education as a model to improve prescribing behaviour among general practitioners. Eur J Clin Pharmacol. 2001;56(11):843-8. [pmid: 11294376].
45 Park JJ, Kelly P, Carter BL, et al. Comprehensive pharmaceutical care in the chain setting. J Am Pharm Assoc. 1996;NS36(7):443-51.
46 Pritchard DA, Hyndman J, Taba F. Nutritional counselling in general practice: a cost effective analysis. J Epidemiol Community Health. 1999;53(5):311-6. [pmid: 10396539]. [pmcid: 1756872].
47 Putnam RW, Curry L. Physicians' participation in establishing criteria for hypertension management in the office: will patient outcomes be improved?. CMAJ. 1989;140(7):806-9. [pmid: 2924230]. [pmcid: 1268807].
48 Rehder TL, McCoy LK, Blackwell B, et al. Improving medication compliance by counseling and special prescription container. Am J Hosp Pharm. 1980;37(3):379-85. [pmid: 7369220].
49 Robson J, Boomla K, Fitzpatrick S, et al. Using nurses for preventive activities with computer assisted follow up: A randomised controlled trial. BMJ. 1989;298(6671):433-6. [pmid: 2495053]. [pmcid: 1835698].
50 Rogers MA, Small D, Buchan DA, et al. Home monitoring service improves mean arterial pressure in patients with essential hypertension. A randomized, controlled trial. Ann Intern Med. 2001;134(11):1024-32. [pmid: 11388815].
51 Sanders KM, Satyvavolu A. Improving blood pressure control in diabetes: limitations of a clinical reminder in influencing physician behavior. J Contin Educ Health Prof. 2002;22(1):23-32. [pmid: 12004637].
52 Saunders LD, Irwig LM, Gear JS, et al. A randomized controlled trial of compliance improving strategies in Soweto hypertensives. Med Care. 1991;29(7):669-78. [pmid: 2072772].
53 Schneider PJ, Larrimer JN, Visconti JA, et al. Role effectiveness of a pharmacist in the maintenance of patients with hypertension and congestive heart failure. Contemp Pharm Pract. 1982;5(2):74-9. [pmid: 10256913].
54 Siscovick DS, Strogatz DS, Wagner EH, et al. Provider-oriented interventions and management of hypertension. Med Care. 1987;25(3):254-8. [pmid: 3821228].
55 Soghikian K, Casper SM, Fireman BH, et al. Home blood pressure monitoring. Effect on use of medical services and medical care costs. Med Care. 1992;30(9):855-65. [pmid: 1518317].
56 Velez R, Anderson L, McFall S, et al. Improving patient follow-up in incidental screening through referral letters. Arch Intern Med. 1985;145(12):2184-7. [pmid: 4074031].
57 Vivian EM. Improving blood pressure control in a pharmacist-managed hypertension clinic. Pharmacotherapy. 2002;22(12):1533-40. [pmid: 12495164].
58 Winickoff RN, Wilner S, Neisuler R, Barnett GO. Limitations of provider interventions in hypertension quality assurance. American Journal of Public Health. 1985;75(1):43-46. [pmid: 3966597]. [pmcid: 1646142].
59 Zarnke KB, Feagan BG, Mahon JL, et al. A randomized study comparing a patient-directed hypertension management strategy with usual office-based care. Am J Hyper. 1997;10(1):58-67.
60 Dickinson, et al. Improving hypertension control: impact of computer feedback and physician education. Med Care. 1981;19:843-54. [pmid: 6153057].
61 Persistence of reduction in blood pressure and mortality of participants in the Hypertension Detection and Follow-up Program. Hypertension Detection and Follow-up Program Cooperative Group. JAMA 1988;259(14):2113–22.
62 Artinian NT, Washington OG, Templin TN. Effects of home telemonitoring and community-based monitoring on blood pressure control in urban African Americans: A pilot study. Heart Lung. 2001;30(3):191-9. [pmid: 11343005].
63 Krishan I, Davis CS, Nobrega FT, et al. The Mayo three-community hypertension control program. IV. Five-year outcomes of intervention in entire communities. Mayo Clin Proc. 1981;56(1):3-10. [pmid: 7453248].
64 Montgomery AA, Fahey T, Peters TJ, et al. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: randomised controlled trial. [Additional comparison]. BMJ. 2000;320(7236):686-90. [pmid: 10710578]. [pmcid: 27312].
65 McGhee SM, McInnes GT, Hedley AJ, et al. Coordinating and standardizing long-term care: evaluation of the west of Scotland shared-care scheme for hypertension. [Additional comparison]. British Journal of General Practice. 1994;44(387):441-5. [pmid: 7748631]. [pmcid: 1239016].
66 Krishan I, Davis CS, Nobrega FT, et al. The Mayo three-community hypertension control program. IV. Five-year outcomes of intervention in entire communities. [Additional comparison]. Mayo Clin Proc. 1981;56(1):3-10. [pmid: 7453248].
67 Goldberg HI, Wagner EH, Fihn SD, et al. A randomized controlled trial of CQI teams and academic detailing: can they alter compliance with guidelines? [Additional comparison]. Jt Comm J Qual Improv. 1998;24(3):130-42. [pmid: 9568553].
68 Dickinson, et al. Improving hypertension control: impact of computer feedback and physician education. [Additional comparison (2)]. Med Care. 1981;19:843. [pmid: 6153057].
69 Gullion DS, Tschann JM, Adamson TE, et al. Management of hypertension in private practices: a randomized controlled trial in continuing medical education. [Additional comparison]. Journal of Continuing Education in the Health Professions. 1988;8:239-55.
70 Velez R, Anderson L, McFall S, et al. Improving patient follow-up in incidental screening through referral letters. [Additional comparison]. Arch Intern Med. 1985;145(12):2184-7. [pmid: 4074031].
71 Velez R, Anderson L, McFall S, et al. Improving patient follow-up in incidental screening through referral letters. [Additional comparison (2)]. Arch Intern Med. 1985;145(12):2184-7. [pmid: 4074031].
72 Foote A, Erfurt JC. Hypertension control at the work site. Comparison of screening and referral alone, referral and follow-up, and on-site treatment. [Additional comparison (2)]. N Engl J Med. 1983;308(14):809-13. [pmid: 6835271].
73 Artinian NT, Washington OG, Templin TN. Effects of home telemonitoring and community-based monitoring on blood pressure control in urban African Americans: a pilot study. [Additional comparison]. Heart Lung. 2001;30(3):191-9. [pmid: 11343005].
74 Dickinson, et al. Improving hypertension control: impact of computer feedback and physician education. [Additional comparison]. Med Care. 1981;19:843. [pmid: 6153057].
75 Rehder TL, McCoy LK, Blackwell B, et al. Improving medication compliance by counseling and special prescription container. [Additional comparison (2)]. Am J Hosp Pharm. 1980;37(3):379-85. [pmid: 7369220].
76 Saunders LD, Irwig LM, Gear JS, et al. A randomized controlled trial of compliance improving strategies in Soweto hypertensives. [Additional comparison]. Med Care. 1991;29(7):669-78. [pmid: 2072772].
77 Pritchard DA, Hyndman J, Taba F. Nutritional counselling in general practice: a cost effective analysis. [Additional comparison]. J Epidemiol Community Health. 1999;53(5):311-6. [pmid: 10396539]. [pmcid: 1756872].
78 Foote A, Erfurt JC. Hypertension control at the work site. Comparison of screening and referral alone, referral and follow-up, and on-site treatment. [Additional comparison]. N Engl J Med. 1983;308(14):809-13. [pmid: 6835271].
79 Earp JA, Ory MG, Strogatz DS. The effects of family involvement and practitioner home visits on the control of hypertension. [Additional comparison]. Am J Public Health. 1982;72(10):1146-54. [pmid: 7114339]. [pmcid: 1650178].
80 McDowell I, Newell C, Rosser W. A randomized trial of computerized reminders for blood pressure screening in primary care. [Additional comparison]. Med Care. 1989;27(3):297-305. [pmid: 2494397].
81 McDowell I, Newell C, Rosser W. A randomized trial of computerized reminders for blood pressure screening in primary care. [Additional comparison (2)]. Med Care. 1989;27(3):297-305. [pmid: 2494397].
82 Vivian EM. Improving blood pressure control in a pharmacist-managed hypertension clinic. [Additional comparison]. Pharmacotherapy. 2002;22(12):1533-40. [pmid: 12495164].