# References

1 Chobanian AV, Bakris GL, Black HR, et al. The seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289(19):2560-72. [pmid: 12748199].
2 The world health report, 2002. Reducing risks, promoting healthy life. Geneva, Switzerland: Work Health Organization; 2002. Report No. 58.
3 Harrison's principles of internal medicine. Thirteenth edition. New York: McGraw-Hill; 1994.
4 Cherry DK, Woodwell DA. National ambulatory medical care survey: 2000 summary. Adv Data 2002(328):1–32.
5 Kannel WB. Framingham study insights into hypertensive risk of cardiovascular disease. Hypertens Res. 1995;18(3):181-96. [pmid: 7584927].
6 Himmelmann A, Hedner T, Hansson L, et al. Isolated systolic hypertension: an important cardiovascular risk factor. Blood Press. 1998;7(4):197-207. [pmid: 9858111].
7 Kannel WB. Hypertension as a risk factor for cardiac events—epidemiologic results of long-term studies. J Cardiovasc Pharmacol. 1993;21(Suppl 2):S27-37. [pmid: 7692148].
8 Collins R, Peto R, MacMahon S, et al. Blood pressure, stroke, and coronary heart disease. Part 2, Short-term reductions in blood pressure: overview of randomised drug trials in their epidemiological context. Lancet. 1990;335(8693):827-38. [pmid: 1969567].
9 MacMahon S, Peto R, Cutler J, et al. Blood pressure, stroke, and coronary heart disease. Part 1, Prolonged differences in blood pressure: prospective observational studies corrected for the regression dilution bias. Lancet. 1990;335(8692):765-74. [pmid: 1969518].
10 Prevention of stroke by antihypertensive drug treatment in older persons with isolated systolic hypertension. Final results of the Systolic Hypertension in the Elderly Program (SHEP). SHEP Cooperative Research Group. JAMA 1991;265(24):3255–64.
11 Dahlof B, Hansson L, Lindholm LH, et al. Swedish trial in old patients with hypertension (STOP-Hypertension) analyses performed up to 1992. Clin Exp Hypertens. 1993;15(6):925-39. [pmid: 7903578].
12 Medical Research Council trial of treatment of hypertension in older adults: principal results. MRC Working Party. BMJ 1992;304(6824):405–12.
13 Cook NR, Cohen J, Hebert PR, et al. Implications of small reductions in diastolic blood pressure for primary prevention. Arch Intern Med. 1995;155(7):701-9. [pmid: 7695458].
14 Lewington S, Clarke R, Qizilbash N, et al. Age-specific relevance of usual blood pressure to vascular mortality: a meta-analysis of individual data for one million adults in 61 prospective studies. Lancet. 2002;360(9349):1903-13. [pmid: 12493255].
15 Approach to the management of hypertension, 3rd ed. Council of High Blood Pressure, American Heart Association; 2003.
16 Hajjar I, Kotchen TA. Trends in prevalence, awareness, treatment, and control of hypertension in the United States, 988–2000. JAMA. 2003;290(2):199-206. [pmid: 12851274].
17 The sixth report of the Joint National Committee on prevention, detection, evaluation, and treatment of high blood pressure. Arch Intern Med 1997;157(21):2413–46.
18 Klag MJ, Whelton PK, Randall BL, et al. End-stage renal disease in African-American and white men. 16-year MRFIT findings. JAMA. 1997;277(16):1293-8. [pmid: 9109467].
19 Gueyffier F, Boutitie F, Boissel JP, et al. Effect of antihypertensive drug treatment on cardiovascular outcomes in women and men. A meta-analysis of individual patient data from randomized, controlled trials. The INDANA Investigators. Ann Intern Med. 1997;126(10):761-7. [pmid: 9148648].
20 Five-year findings of the hypertension detection and follow-up program. II. Mortality by race-sex and age. Hypertension Detection and Follow-up Program Cooperative Group. JAMA 1979;242(23):2572–7.
21 Ooi WL, Budner NS, Cohen H, et al. Impact of race on treatment response and cardiovascular disease among hypertensives. Hypertension. 1989;14(3):227-34. [pmid: 2767755].
22 Healthy People 2010. http://www.healthypeople.gov/Document/HTML/Volume1/12Heart.htm Accessed November 2003
23 National Center for Health Statistics. 2003 National Health Interview Survey (NHIS). http://www.cdc.gov/nchs/nhis.htm Accessed November 2003
24 Carter BL. Blood pressure as a surrogate end point for hypertension. Ann Pharmacother. 2002;36(1):87-92. [pmid: 11816267].
25 Turnbull F. Effects of different blood-pressure-lowering regimens on major cardiovascular events: results of prospectively-designed overviews of randomised trials. Lancet. 2003;362(9395):1527-35. [pmid: 14615107].
26 1999 World Health Organization-International Society of Hypertension guidelines for the management of hypertension. Guidelines Subcommittee. J Hypertens 1999;17(2):151–83.
27 Diagnosis and management of hypertension in the primary care setting. Washington, DC: VA/DoD Evidence-Based Clinical Practice Guideline Working Group, Veterans Health Administration, Department of Veterans Affairs, and Health Affairs, Department of Defense; 1999 November. Office of Quality and Performance publication no. 10Q-CPG/HTN-99.
28 Chassin MR, Galvin RW. The urgent need to improve health care quality. Institute of Medicine National Roundtable on Health Care Quality. JAMA. 1998;280(11):1000-5. [pmid: 9749483].
29 Agency for Healthcare Research and Quality, July 2002. NHQR preliminary measure set. Background. http://www.ahrq.gov/qual/nhqr02/nhqrprelim.htm Accessed August 28 2003.
30 A comprehensive framework for hospital care performance evaluation. Washington, DC: National Quality Forum; 2003.
31 Centers for Medicaid and Medicare Services, 2003. Quality Initiatives. http://www.cms.hhs.gov/quality/ Accessed November 2003.
32 Envisioning the national health care quality report. Commitee on the National Quality Report on Health Care Delivery, Institute of Medicine. Washington, D.C.: National Academy Press; 2001.
33 National Committee for Quality Assurance. HEDIS 2001. Washington D.C.: NCQA; 2000.
34 National Committee for Quality Assurance. The State of Managed Care Quality. Washington D.C.: NCQA; 2001.
35 Office of Quality and Performance (10Q). Fiscal Year 2002 VHA performance measurement system technical manual. Technical Manual. Washington (DC): Veterans Health Administration (VHA); 2002.
36 Thomson O'Brien MA, Oxman AD, Haynes RB, et al. Local opinion leaders: effects on professional practice and health care outcomes. Cochrane Database Syst Rev 2000(2):CD000125.
37 Berner ES, Baker CS, Funkhouser E, et al. Do local opinion leaders augment hospital quality improvement efforts? A randomized trial to promote adherence to unstable angina guidelines. Med Care. 2003;41(3):420-31. [pmid: 12618645].
38 Gross PA, Greenfield S, Cretin S, et al. Optimal methods for guideline implementation: Conclusions from Leeds Castle meeting. Med Care. 2001;39(8 Suppl 2):II85-92. [pmid: 11583124].
39 Slotnick HB, Shershneva MB. Use of theory to interpret elements of change. J Contin Educ Health Prof. 2002;22(4):197-204. [pmid: 12613054].
40 Campbell M, Fitzpatrick R, Haines A, et al. Framework for design and evaluation of complex interventions to improve health. BMJ. 2000;321(7262):694-6. [pmid: 10987780]. [pmcid: 1118564].
41 Stone EG, Morton SC, Hulscher ME, et al. Interventions that increase use of adult immunization and cancer screening services: A meta-analysis. Ann Intern Med. 2002;136(9):641-51. [pmid: 11992299].
42 Hulscher ME, Laurant MG, Grol RP. Process evaluation on quality improvement interventions. Qual Saf Health Care. 2003;12(1):40-6. [pmid: 12571344]. [pmcid: 1743654].
43 Hulscher ME, van Drenth BB, Mokkink HG, et al. Barriers to preventive care in general practice: The role of organizational and attitudinal factors. Br J Gen Pract. 1997;47(424):711-4. [pmid: 9519516]. [pmcid: 1409944].
44 Glasgow RE, Hampson SE, Strycker LA, et al. Personal-model beliefs and social-environmental barriers related to diabetes self-management. Diabetes Care. 1997;20(4):556-61. [pmid: 9096980].
45 Renders CM, Valk GD, Griffin S, et al. Interventions to improve the management of diabetes mellitus in primary care, outpatient and community settings. Cochrane Database Syst Rev 2001(1):CD001481.
46 Renders CM, Valk GD, Griffin SJ, et al. Interventions to improve the management of diabetes in primary care, outpatient, and community settings: a systematic review. Diabetes Care. 2001;24(10):1821-33. [pmid: 11574449].
47 Cochrane Effective Practice and Organisation of Care Group, November 12, 2003. Effective Practice and Organisation of Care Group. http://www.epoc.uottawa.ca/index.htm Accessed November 2003
48 Alderman M. Detection and treatment of high blood pressure at the work place. In: High blood pressure control in the work setting. Bethesda, MD: National High Blood Pressure Education Program; 1976. p. 33–45.
49 Berwick DM. Screening in health fairs. A critical review of benefits, risks, and costs. JAMA. 1985;254(11):1492-8. [pmid: 3928913].
50 Devine EC, Reifschneider E. A meta-analysis of the effects of psychoeducational care in adults with hypertension. Nurs Res. 1995;44(4):237-45. [pmid: 7624235].
51 DiMatteo MR, Giordani PJ, Lepper HS, et al. Patient adherence and medical treatment outcomes: a meta-analysis. Med Care. 2002;40(9):794-811. [pmid: 12218770].
52 Ebrahim S. Detection, adherence and control of hypertension for the prevention of stroke: a systematic review. Health Technol Assess 1998;2(11):i–iv, 1–78.
53 Fitzmaurice DA, Adams JL. A systematic review of patient information leaflets for hypertension. J Hum Hypertens. 2000;14(4):259-62. [pmid: 10805051].
54 Freis ED. Improving treatment effectiveness in hypertension. Arch Intern Med. 1999;159(21):2517-21. [pmid: 10573041].
55 Hooper L, Bartlett C, Davey Smith G, et al. Systematic review of long term effects of advice to reduce dietary salt in adults. BMJ. 2002;325(7365):628. [pmid: 12242173].
56 Iskedjian M, Einarson TR, MacKeigan LD, et al. Relationship between daily dose frequency and adherence to antihypertensive pharmacotherapy: evidence from a meta-analysis. Clin Ther. 2002;24(2):302-16. [pmid: 11911560].
57 Macharia WM, Leon G, Rowe BH, et al. An overview of interventions to improve compliance with appointment keeping for medical services. JAMA. 1992;267(13):1813-7. [pmid: 1532036].
58 Mallion JM, Baguet JP, Siche JP, et al. Compliance, electronic monitoring and antihypertensive drugs. J Hypertens Suppl. 1998;16(1):S75-9. [pmid: 9534102].
59 Mant D. Effectiveness of dietary intervention in general practice. Am J Clin Nutr. 1997;65(6 Suppl):1933S-1938S. [pmid: 9174497].
60 McDonald HP, Garg AX, Haynes RB. Interventions to enhance patient adherence to medication prescriptions: scientific review. JAMA. 2002;288(22):2868-79. [pmid: 12472329].
61 Montgomery AA, Fahey T. A systematic review of the use of computers in the management of hypertension. J Epidemiol Community Health. 1998;52(8):520-5. [pmid: 9876364]. [pmcid: 1756753].
62 Oxman AD, Thomson MA, Davis DA, et al. No magic bullets: a systematic review of 102 trials of interventions to improve professional practice. CMAJ. 1995;153(10):1423-31. [pmid: 7585368]. [pmcid: 1487455].
63 Roter DL, Hall JA, Merisca R, et al. Effectiveness of interventions to improve patient compliance: a meta-analysis. Med Care. 1998;36(8):1138-61. [pmid: 9708588].
64 Rybacki JJ. Improving cardiovascular health in postmenopausal women by addressing medication adherence issues. J Am Pharm Assoc. 2002;42(1):63-71. quiz 72–3.
65 Staessen JA, Thijs L. Development of diagnostic thresholds for automated self-measurement of blood pressure in adults. First International Consensus Conference on Blood Pressure Self-Measurement. Blood Press Monit. 2000;5(2):101-9. [pmid: 10828897].
66 Thomson O'Brien MA, Oxman AD, Davis DA, et al. Educational outreach visits: effects on professional practice and health care outcomes. Cochrane Database Syst Rev 2000(2):CD000409.
67 Thomson O'Brien MA, Oxman AD, Davis DA, et al. Audit and feedback versus alternative strategies: effects on professional practice and health care outcomes. Cochrane Database Syst Rev 2000(2):CD000260.
68 Tu K, Davis D. Can we alter physician behavior by educational methods? Lessons learned from studies of the management and follow-up of hypertension. J Contin Educ Health Prof. 2002;22(1):11-22. [pmid: 12004636].
69 Vijan S, Stevens DL, Herman WH, et al. Screening, prevention, counseling, and treatment for the complications of type II diabetes mellitus. Putting evidence into practice. J Gen Intern Med. 1997;12(9):567-80. [pmid: 9294791]. [pmcid: 1497162].
70 Worrall G, Chaulk P, Freake D. The effects of clinical practice guidelines on patient outcomes in primary care: a systematic review. CMAJ. 1997;156(12):1705-12. [pmid: 9220922]. [pmcid: 1227585].
71 Multiple Risk Factor Intervention Trial Research Group. Multiple risk factor intervention trial. Risk factor changes and mortality results. JAMA. 1982;248(12):1465-77. [pmid: 7050440].
72 Schoenberger J. Health disease in industry: the Chicago Heart Association Project. In: High blood pressure control in the work setting. Bethesda, MD: National High Blood Pressure Education Program; 1976. p. 46–58.
73 Foote A, Erfurt JA. Model system for high blood pressure control in the work setting. In: High blood pressure control in the work setting. Bethesda, MD: National High Blood Pressure Education Program; 1976. p. 58–60.
74 Murphy AF. The Burlington Industries Industrial Hypertension Program. In: High blood pressure control in the work setting. Bethesda, MD: National High Blood Pressure Education Program; 1976. p. 30–33.
75 Watkins CJ, Papacosta AO, Chinn S, et al. A randomized controlled trial of an information booklet for hypertensive patients in general practice. J R Coll Gen Pract. 1987;37(305):548-50. [pmid: 3503941]. [pmcid: 1711180].
76 Binstock M, Granklin K, Formica E. Therapeutic adherence programme improves compliance and lowers blood pressure. J Hypertens. 1986;4(Suppl. 5):S375-77.
77 Hovell MF, Geary DC, Black DR, et al. The effects of lay counseling on medication adherence and blood pressure: Adjunctive treatment for hypertension. Patient Educ Couns. 1984;6(2):91-4. [pmid: 10268102].
78 Baranowski T, Chapin J, Evans M, et al. Utilization and medication compliance for high blood pressure: An experiment with family involvement and self blood pressure monitoring in a rural population. In: Third National Symposium on Patient Education; 1980. p. 51–67.
79 Barry SP, Daniels AA. Effecting change in outpatient failed appointments. J Fam Pract. 1984;18(5):739-42. [pmid: 6716071].
80 Stahl SM, Kelley CR, Neill PJ, et al. Effects of home blood pressure measurement on long-term BP control. Am J Public Health. 1984;74(7):704-9. [pmid: 6742256]. [pmcid: 1651666].
81 Webb PA. Effectiveness of patient education and psychosocial counseling in promoting compliance and control among hypertensive patients. J Fam Pract. 1980;10(6):1047-55. [pmid: 7373255].
82 Cooke CJ, Meyers A. The role of community volunteers in health interventions: a hypertension screening and follow-up program. Am J Public Health. 1983;73(2):193-4. [pmid: 6849477]. [pmcid: 1650519].
83 Grimshaw J, Thomas R, MacLennan G, et al. Effectiveness and efficiency of guideline dissemination and implementation strategies. Health Technol Asess. 2004;8(6):1-84.
84 Burdett S, Stewart LA, Tierney JF. Publication bias and meta-analyses: a practical example. Int J Technol Assess Health Care. 2003;19(1):129-34. [pmid: 12701945].
85 Chalmers TC, Frank CS, Reitman D. Minimizing the three stages of publication bias. JAMA. 1990;263(10):1392-5. [pmid: 2406473].
86 Dickersin K. The existence of publication bias and risk factors for its occurrence. JAMA. 1990;263(10):1385-9. [pmid: 2406472].
87 Klassen TP, Wiebe N, Russell K, et al. Abstracts of randomized controlled trials presented at the Society for Pediatric Research meeting: an example of publication bias. Arch Pediatr Adolesc Med. 2002;156(5):474-9. [pmid: 11980553].
88 Krzyzanowska MK, Pintilie M, Tannock IF. Factors associated with failure to publish large randomized trials presented at an oncology meeting. JAMA. 2003;290(4):495-501. [pmid: 12876092].
89 Stern JM, Simes RJ. Publication bias: evidence of delayed publication in a cohort study of clinical research projects. BMJ. 1997;315(7109):640-5. [pmid: 9310565]. [pmcid: 2127436].
90 Sutton AJ, Duval SJ, Tweedie RL, et al. Empirical assessment of effect of publication bias on meta-analyses. BMJ. 2000;320(7249):1574-7. [pmid: 10845965]. [pmcid: 27401].
91 Sutton AJ, Song F, Gilbody SM, et al. Modeling publication bias in meta-analysis: a review. Stat Methods Med Res. 2000;9(5):421-45. [pmid: 11191259].
92 Macaskill P, Walter SD, Irwig L. A comparison of methods to detect publication bias in meta-analysis. Stat Med. 2001;20(4):641-54. [pmid: 11223905].
93 Pham B, Platt R, McAuley L, et al. Is there a “best” way to detect and minimize publication bias? An empirical evaluation. Eval Health Prof. 2001;24(2):109-25. [pmid: 11523382].
94 McAuley L, Pham B, Tugwell P, et al. Does the inclusion of grey literature influence estimates of intervention effectiveness reported in meta-analyses?. Lancet. 2000;356(9237):1228-31. [pmid: 11072941].
95 Cook DJ, Guyatt GH, Ryan G, et al. Should unpublished data be included in meta-analyses? Current convictions and controversies. JAMA. 1993;269(21):2749-53. [pmid: 8492400].
96 Campbell MK, Mollison J, Grimshaw JM. Cluster trials in implementation research: Estimation of intracluster correlation coefficients and sample size. Stat Med. 2001;20(3):391-9. [pmid: 11180309].
97 Kerry SM, Bland JM. Sample size in cluster randomisation. BMJ. 1998;316(7130):549. [pmid: 9501723].
98 Kerry SM, Bland JM. The intracluster correlation coefficient in cluster randomisation. BMJ. 1998;316(7142):1455. [pmid: 9572764]. [pmcid: 1113123].
99 Torgerson DJ. Contamination in trials: Is cluster randomisation the answer?. BMJ. 2001;322(7282):355-7. [pmid: 11159665]. [pmcid: 1119583].
100 Donner A, Klar N. Issues in the meta-analysis of cluster randomized trials. Stat Med. 2002;21(19):2971-80. [pmid: 12325113].
101 Donner A, Piaggio G, Villar J. Statistical methods for the meta-analysis of cluster randomization trials. Stat Methods Med Res. 2001;10(5):325-38. [pmid: 11697225].
102 Donner A, Piaggio G, Villar J. Meta-analyses of cluster randomization trials. Power considerations. Eval Health Prof. 2003;26(3):340-51. [pmid: 12971203].
103 Localio AR, Berlin JA, Ten Have TR, et al. Adjustments for center in multicenter studies: An overview. Ann Intern Med. 2001;135(2):112-23. [pmid: 11453711].
104 Hahn G, Meeker W. Statistical Intervals: A Guide for Practitioners. New York: John Wiley & Sons, Inc; 1991.
105 Mortality after 10 1/2 years for hypertensive participants in the Multiple Risk Factor Intervention Trial. Circulation 1990;82(5):1616–28.
106 Aubin M, Vezina L, Fortin JP, et al. Effectiveness of a program to improve hypertension screening in primary care. CMAJ. 1994;150(4):509-15. [pmid: 8313262]. [pmcid: 1486287].
107 Aucott JN, Pelecanos E, Dombrowski R, et al. Implementation of local guidelines for cost-effective management of hypertension. A trial of the firm system. J Gen Intern Med. 1996;11(3):139-46. [pmid: 8667090].
108 Avanzini F, Corsetti A, Maglione T, et al. Simple, shared guidelines raise the quality of antihypertensive treatment in routine care. Am Heart J. 2002;144(4):726-32. [pmid: 12360171].
109 Barnett GO, Winickoff RN, Morgan MM, et al. A computer-based monitoring system for follow-up of elevated blood pressure. Med Care. 1983;21(4):400-9. [pmid: 6341724].
110 Bass MJ, McWhinney IR, Donner A. Do family physicians need medical assistants to detect and manage hypertension?. CMAJ. 1986;134(11):1247-55. [pmid: 2871915]. [pmcid: 1491080].
111 Becker LA, Glanz K, Sobel E, et al. A randomized trial of special packaging of antihypertensive medications. J Fam Pract. 1986;22(4):357-61. [pmid: 3958683].
112 Blenkinsopp A, Phelan M, Bourne J, et al. Extended adherence support by community pharmacists for patients with hypertension: A randomised controlled trial. International Journal of Pharmacy Practice. 2000;8(3):165-175.
113 Bogden PE, Abbott RD, Williamson P, et al. Comparing standard care with a physician and pharmacist team approach for uncontrolled hypertension. J Gen Intern Med. 1998;13(11):740-5. [pmid: 9824519]. [pmcid: 1497023].
114 Borenstein JE, Graber G, Saltiel E, et al. Physician-pharmacist comanagement of hypertension: A randomized, comparative trial. Pharmacotherapy. 2003;23(2):209-16. [pmid: 12587810].
115 Brook RH, Ware JE Jr, Rogers WH, et al. Does free care improve adults' health?. N Engl J Med. 1983;309(23):1426-1434. [pmid: 6355851].
116 Campbell NC, Ritchie LD, Thain J, et al. Secondary prevention in coronary heart disease: A randomised trial of nurse led clinics in primary care. Heart. 1998;80(5):447-52. [pmid: 9930042]. [pmcid: 1728827].
117 Carter BL, Barnette DJ, Chrischilles E, et al. Evaluation of hypertensive patients after care provided by community pharmacists in a rural setting. Pharmacotherapy. 1997;17(6):1274-85. [pmid: 9399611].
118 Curzio JL, Rubin PC, Kennedy SS, et al. A comparison of the management of hypertensive patients by nurse practitioners compared with conventional hospital care. J Hum Hypertens. 1990;4(6):665-70. [pmid: 2096208].
119 Earp JA, Ory MG, Strogatz DS. The effects of family involvement and practitioner home visits on the control of hypertension. Am J Public Health. 1982;72(10):1146-54. [pmid: 7114339]. [pmcid: 1650178].
120 Erfurt JC, Foote A, Heirich MA. Worksite wellness programs: incremental comparison of screening and referral alone, health education, follow-up counseling, and plant organization. Am J Health Promot. 1991;5(6):438-48. [pmid: 10148672].
121 Erickson SR, Slaughter R, Halapy H. Pharmacists' ability to influence outcomes of hypertension therapy. Pharmacotherapy. 1997;17(1):140-7. [pmid: 9017775].
122 Evans CE, Haynes RB, Birkett NJ, et al. Does a mailed continuing education program improve physician performance? Results of a randomized trial in antihypertensive care. JAMA. 1986;255(4):501-4. [pmid: 3941533].
123 Forstrom MJ, Ried LD, Stergachis AS, et al. Effect of a clinical pharmacist program on the cost of hypertension treatment in an HMO family practice clinic. DICP. 1990;24(3):304-9. [pmid: 2316237].
124 Fortmann SP, Winkleby MA, Flora JA, et al. Effect of long-term community health education on blood pressure and hypertension control. The Stanford Five-City Project. American Journal of Epidemiology. 1990;132(4):629-646. [pmid: 2403104].
125 Friedman RH, Kazis LE, Jette A, et al. A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control. Am J Hypertens. 1996;9(4 Pt 1):285-92. [pmid: 8722429].
126 Garcao JA, Cabrita J. Evaluation of a pharmaceutical care program for hypertensive patients in rural Portugal. J Am Pharm Assoc. 2002;42(6):858-64.
127 Garcia-Pena C, Thorogood M, Armstrong B, et al. Pragmatic randomized trial of home visits by a nurse to elderly people with hypertension in Mexico. Int J Epidemiol. 2001;30(6):1485-91. [pmid: 11821367].
128 Goldberg HI, Wagner EH, Fihn SD, et al. A randomized controlled trial of CQI teams and academic detailing: Can they alter compliance with guidelines?. Jt Comm J Qual Improv. 1998;24(3):130-42. [pmid: 9568553].
129 Gullion DS, Tschann JM, Adamson TE, et al. Management of hypertension in private practices: A randomized controlled trial in continuing medical education. J Contin Educ Health Prof. 1988;8:239-255.
130 Hetlevik I, Holmen J, Kruger O. Implementing clinical guidelines in the treatment of hypertension in general practice. Evaluation of patient outcome related to implementation of a computer-based clinical decision support system. Scand J Prim Health Care. 1999;17(1):35-40. [pmid: 10229991].
131 Hill MN, Bone LR, Hilton SC, et al. A clinical trial to improve high blood pressure care in young urban black men: recruitment, follow-up, and outcomes. Am J Hypertens. 1999;12(6):548-54. [pmid: 10371363].
132 Hla KM, Feussner JR, Blessing-Feussner CL, et al. BP control. Improvement in a university medical clinic by use of a physician's associate. Arch Intern Med. 1983;143(5):920-3. [pmid: 6148049].
133 Jennett PA, Wilson TW, Hayton RC, et al. Desirable behaviours in the office management of hypertension addressed through continuing medical education. Can J Public Health. 1989;80(5):359-62. [pmid: 2804866].
134 Jewell D, Hope J. Evaluation of a nurse-run hypertension clinic in general practice. Practitioner. 1988;232(1447):484-7. [pmid: 3249732].
135 Kogan JR, Reynolds EE, Shea JA. Effectiveness of report cards based on chart audits of residents' adherence to practice uidelines on practice performance: A randomized controlled trial. Teach Learn Med. 2003;15(1):25-30. [pmid: 12632705].
136 Logan AG, Milne BJ, Achber C, et al. Cost-effectiveness of a worksite hypertension treatment program. Hypertension. 1981;3(2):211-18. [pmid: 6783519].
137 Logan AG, Milne BJ, Flanagan PT, et al. Clinical effectiveness and cost-effectiveness of monitoring blood pressure of hypertensive employees at work. Hypertension. 1983;5(6):828-36. [pmid: 6418647].
138 Markov KV, Smirnov YV. Prospective epidemiological study of arterial hypertension under preventive measures. Cor Vasa. 1986;28(3):161-6. [pmid: 3743085].
139 McAlister NH, Covvey HD, Tong C, et al. Randomised controlled trial of computer assisted management of hypertension in primary care. BMJ (Clin Res Ed). 1986;293(6548):670-4.
140 McClellan WM, Craxton LC. Improved follow-up care of hypertensive patients by a nurse practitioner in a rural clinic. J Rural Health. 1985;1(2):34-41. [pmid: 10279389].
141 McDowell I, Newell C, Rosser W. A randomized trial of computerized reminders for blood pressure screening in primary care. Med Care. 1989;27(3):297-305. [pmid: 2494397].
142 McGhee SM, McInnes GT, Hedley AJ, et al. Coordinating and standardizing long-term care: Evaluation of the west of Scotland shared-care scheme for hypertension. Br J Gen Pract. 1994;44(387):441-5. [pmid: 7748631]. [pmcid: 1239016].
143 Mehos BM, Saseen JJ, MacLaughlin EJ. Effect of pharmacist intervention and initiation of home blood pressure monitoring in patients with uncontrolled hypertension. Pharmacotherapy. 2000;20(11):1384-9. [pmid: 11079287].
144 Midanik LT, Resnick B, Hurley LB, et al. Home blood pressure monitoring for mild hypertensives. Public Health Rep. 1991;106(1):85-9. [pmid: 1899945]. [pmcid: 1580210].
145 Montgomery AA, Fahey T, Peters TJ, et al. Evaluation of computer based clinical decision support system and risk chart for management of hypertension in primary care: Randomised controlled trial. BMJ. 2000;320(7236):686-90. [pmid: 10710578]. [pmcid: 27312].
146 Nilsson G, Hjemdahl P, Hassler A, et al. Feedback on prescribing rate combined with problem-oriented pharmacotherapy education as a model to improve prescribing behaviour among general practitioners. Eur J Clin Pharmacol. 2001;56(11):843-8. [pmid: 11294376].
147 Park JJ, Kelly P, Carter BL, et al. Comprehensive pharmaceutical care in the chain setting. J Am Pharm Assoc. 1996;NS36(7):443-51.
148 Pritchard DA, Hyndman J, Taba F. Nutritional counseling in general practice: a cost effective analysis. J Epidemiol Community Health. 1999;53(5):311-6. [pmid: 10396539]. [pmcid: 1756872].
149 Putnam RW, Curry L. Physicians' participation in establishing criteria for hypertension management in the office: Will patient outcomes be improved?. CMAJ. 1989;140(7):806-9. [pmid: 2924230]. [pmcid: 1268807].
150 Rehder TL, McCoy LK, Blackwell B, et al. Improving medication compliance by counseling and special prescription container. Am J Hosp Pharm. 1980;37(3):379-85. [pmid: 7369220].
151 Robson J, Boomla K, Fitzpatrick S, et al. Using nurses for preventive activities with computer assisted follow up: A randomised controlled trial. BMJ. 1989;298(6671):433-6. [pmid: 2495053]. [pmcid: 1835698].
152 Rogers MA, Small D, Buchan DA, et al. Home monitoring service improves mean arterial pressure in patients with essential hypertension. A randomized, controlled trial. Ann Intern Med. 2001;134(11):1024-32. [pmid: 11388815].
153 Sanders KM, Satyvavolu A. Improving blood pressure control in diabetes: Limitations of a clinical reminder in influencing physician behavior. J Contin Educ Health Prof. 2002;22(1):23-32. [pmid: 12004637].
154 Saunders LD, Irwig LM, Gear JS, et al. A randomized controlled trial of compliance improving strategies in Soweto hypertensives. Med Care. 1991;29(7):669-78. [pmid: 2072772].
155 Schneider PJ, Larrimer JN, Visconti JA, et al. Role effectiveness of a pharmacist in the maintenance of patients with hypertension and congestive heart failure. Contemp Pharm Pract. 1982;5(2):74-9. [pmid: 10256913].
156 Siscovick DS, Strogatz DS, Wagner EH, et al. Provider-oriented interventions and management of hypertension. Med Care. 1987;25(3):254-8. [pmid: 3821228].
157 Soghikian K, Casper SM, Fireman BH, et al. Home blood pressure monitoring. Effect on use of medical services and medical care costs. Med Care. 1992;30(9):855-65. [pmid: 1518317].
158 Velez R, Anderson L, McFall S, et al. Improving patient follow-up in incidental screening through referral letters. Arch Intern Med. 1985;145(12):2184-7. [pmid: 4074031].
159 Vivian EM. Improving blood pressure control in a pharmacist-managed hypertension clinic. Pharmacotherapy. 2002;22(12):1533-40. [pmid: 12495164].
160 Winickoff RN, Wilner S, Neisuler R, et al. Limitations of provider interventions in hypertension quality assurance. Am J Public Health. 1985;75(1):43-6. [pmid: 3966597]. [pmcid: 1646142].
161 Zarnke KB, Feagan BG, Mahon JL, et al. A randomized study comparing a patient-directed hypertension management strategy with usual office-based care. Am J Hypertens. 1997;10(1):58-67. [pmid: 9008249].
162 Solomon DK. Clinical and economic outcomes in the hypertension and COPD arms of a multicemeter outcomes study. J Am Pharm Assoc. 1998;38:574-85.
163 Persistence of reduction in blood pressure and mortality of participants in the Hypertension Detection and Follow-up Program. Hypertension Detection and Follow-up Program Cooperative Group. JAMA 1988;259(14):2113–22.
164 Artinian NT, Washington OG, Templin TN. Effects of home telemonitoring and community-based monitoring on blood pressure control in urban African Americans: A pilot study. Heart Lung. 2001;30(3):191-9. [pmid: 11343005].
165 Krishan I, Davis CS, Nobrega FT, et al. The Mayo three-community hypertension control program, Part IV. Five-year outcomes of intervention in entire communities. Mayo Clin Proc. 1981;56(1):3-10. [pmid: 7453248].
166 Foote A, Erfurt JC. Hypertension control at the work site. Comparison of screening and referral alone, referral and follow-up, and on-site treatment. N Engl J Med. 1983;308(14):809-13. [pmid: 6835271].
167 Krishan I, Davis CS, Nobrega FT, et al. The Mayo three-community hypertension control program, Part IV. Five-year outcomes of intervention in entire communities. [Additional comparison]. Mayo Clin Proc. 1981;56(1):3-10. [pmid: 7453248].
168 Goldberg HI, Wagner EH, Fihn SD, et al. A randomized controlled trial of CQI teams and academic detailing: Can they alter compliance with guidelines? [Additional comparison]. Jt Comm J Qual Improv. 1998;24(3):130-42. [pmid: 9568553].
169 Salonen JT, Puska P, Kottke TE, et al. Changes in smoking, serum cholesterol and blood pressure levels during a community-based cardiovascular disease prevention program—the North Karelia Project. Am J Epidemiol. 1981;114(1):81-94. [pmid: 6972694].
170 Kizer KW, Demakis JG, Feussner JR. Reinventing VA health care: Systematizing quality improvement and quality innovation. Med Care. 2000;38(6 Suppl 1):I 7-16. [pmid: 10630716].
171 Jha AK, Perlin JB, Kizer KW, et al. Effect of the transformation of the Veterans Affairs health care system on the quality of care. N Engl J Med. 2003;348(22):2218-27. [pmid: 12773650].
172 Hill MN, Han HR, Dennison CR, et al. Hypertension care and control in underserved urban African-American men: Behavioral and physiologic outcomes at 36 months. Am J Hypertens. 2003;16(11 Pt. 1):906-13. [pmid: 14573327].
173 Jamtvedt G, Young JM, Kristoffersen DT, et al. Audit and feedback: Effects on professional practice and health care outcomes. Cochrane Database Syst Rev 2003(3):CD000259.
174 Tversky A, Kahneman D. Judgment under uncertainty: Heuristics and biases. Science. 1974;185(4157):1124-31. [pmid: 17835457].
175 Cabana MD, Rand CS, Powe NR, et al. Why don't physicians follow clinical practice guidelines? A framework for improvement. JAMA. 1999;282(15):1458-65. [pmid: 10535437].
176 Phillips LS, Branch WT, Cook CB, et al. Clinical inertia. Ann Intern Med. 2001;135(9):825-34. [pmid: 11694107].
177 Grimshaw JM, Shirran L, Thomas R, et al. Changing provider behavior: An overview of systematic reviews of interventions. Med Care. 2001;39(8 Suppl 2):II 2-45.
178 Berlowitz DR, Ash AS, Hickey EC, et al. Outcomes of hypertension care. Simple measures are not that simple. Med Care. 1997;35(7):742-6. [pmid: 9219500].
179 Crossing the quality chasm: A new health system for the 21st Century. Institute of Medicine. Washington, D.C.: National Academy Press; 2001.
180 Balas EA, Weingarten S, Garb CT, et al. Improving preventive care by prompting physicians. Arch Intern Med. 2000;160(3):301-8. [pmid: 10668831].
181 Grol R, Grimshaw J. From best evidence to best practice: effective implementation of change in patients' care. Lancet. 2003;362:1225-30. [pmid: 14568747].
182 Shea S, DuMouchel W, Bahamonde L. A meta-analysis of 16 randomized controlled trials to evaluate computer-based clinical reminder systems for preventive care in the ambulatory setting. J Am Med Inform Assoc. 1996;3(6):399-409. [pmid: 8930856]. [pmcid: 116324].
183 Johnston ME, Langton KB, Haynes RB, et al. Effects of computer-based clinical decision support systems on clinician performance and patient outcome. A critical appraisal of research. Ann Intern Med. 1994;120(2):135-42. [pmid: 8256973].
184 Hunt DL, Haynes RB, Hanna SE, et al. Effects of computer-based clinical decision support systems on physician performance and patient outcomes: A systematic review. JAMA. 1998;280(15):1339-46. [pmid: 9794315].
185 Fitzmaurice JM, Adams K, Eisenberg JM. Three decades of research on computer applications in health care: Medical informatics support at the Agency for Healthcare Research and Quality. J Am Med Inform Assoc. 2002;9(2):144-60. [pmid: 11861630]. [pmcid: 344572].
186 Demakis JG, Beauchamp C, Cull WL, et al. Improving residents' compliance with standards of ambulatory care: Results from the VA Cooperative Study on Computerized Reminders. JAMA. 2000;284(11):1411-6. [pmid: 10989404].
187 Moher D, Schulz KF, Altman D. The CONSORT statement: Revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. 2001;285(15):1987-91. [pmid: 11308435].
188 Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med. 2001;134(8):663-94. [pmid: 11304107].
189 Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials. The CONSORT statement. JAMA. 1996;276(8):637-9. [pmid: 8773637].
190 Sackett D, Haynes R, Tugwell P, et al. Clinical epidemiology: A basic science for clinical medicine. 2nd ed. Boston/Toronto/London: Little, Brown and Company; 1991.
191 Lenfant C. Reflections on hypertension control rates: A message from the director of the National Heart, Lung, and Blood Institute. Arch Intern Med. 2002;162(2):131-2. [pmid: 11802745].