# Summary

## Introduction

In early 2003, the Institute of Medicine (IOM) released its report, Priority Areas for National Action: Transforming Health Care Quality. The report listed 20 clinical topics for which “best practices” were strongly supported by clinical evidence. The report—along with other literature—clearly documents the disappointingly low rates at which these practices have been implemented in the United States, at an annual cost of many thousands of lives.

To bring data to bear on the quality improvement opportunities articulated in the IOM's 2003 report, the Agency for Healthcare Research and Quality (AHRQ) engaged the Stanford-UCSF Evidence-based Practice Center (EPC) to perform a critical analysis of the existing literature on quality improvement strategies for a selection of the 20 disease and practice priorities noted in the IOM Report. Rather than concentrating on the specific clinical practices that appear to improve health outcomes, the focus of this review is on translating research into practice—identifying those activities that increase the rate at which practices regarded as effective are applied to patient care in real world settings. In other words, the authors aim to narrow the “quality gap” that is in large part responsible for suboptimal health care practices and outcomes.

This report focuses on the clinical problem of hypertension. It, like the other reports in the series, aims to help readers assess whether the evidence suggests that a quality improvement strategy would work in their specific practice or with their specific patient population. The question of whether these may be crosscutting practices—that is, the manner in which those that have been studied for specific conditions such as hypertension might be applicable to others, such as asthma—remains to be seen. We will further address these practices in subsequent volumes, as we review the evidence for many of the other conditions highlighted in the 2003 IOM report.

We defined the quality gap as the difference between health care processes or outcomes observed in practice, and those potentially obtainable on the basis of current professional knowledge. We defined a quality improvement (QI) strategy as an intervention aimed at reducing the quality gap for a group of patients representative of those encountered in routine practice. Finally, a quality improvement target is an outcome, process, or structure that the QI strategy aims to influence, with the goal of reducing the quality gap. Examples of targets relevant to this volume include outcomes such as reductions in blood pressure, or processes such as improved provider adherence with medication choices in patients with hypertension. Nine types of QI strategies were considered; they are shown (with examples) in Table 1.

Table 1 Taxonomy of QI strategies with examples of substrategies

QI strategy | Examples
Provider reminder systems | - Reminders in charts for providers; - Computer-based reminders for providers; - Computer-based decision support
Facilitated relay of clinical data to providers | - Transmission of clinical data from outpatient specialty clinic to primary care provider by means other than medical record, e.g., phone call or fax
Audit and feedback | - Feedback of performance to individual providers; - Quality indicators and reports; - National/state quality report cards; - Publicly released performance data; - Benchmarking - provision of outcomes data from top performers for comparison with provider's own data
Provider education | - Workshops and conferences; - Educational outreach visits (e.g., academic detailing); - Distribution of educational materials
Patient education | - Classes; - Parent and family education; - Patient pamphlets; - Intensive education strategies promoting self-management of chronic conditions
Promotion of self-management | - Materials and devices to promote self-management
Patient reminder systems | - Postcards or calls to patients
Organizational change | - Case Management, Disease Management; - Total Quality Management, Cycles of Quality Improvement; - Multidisciplinary teams; - Change from paper to computer-based records; - Increased staffing; - Skill mix changes
Financial incentives, regulation, and policy | Provider Directed:; - Financial incentives based on achievement of performance goals; - Alternative reimbursement systems (e.g., fee-for-service, capitated payments); - Licensure requirements
| Patient Directed:; - Co-payments for certain visit types; - Health insurance premiums, user fees
| Health System Directed:; - Initiatives by accreditation bodies (e.g., residency work hour limits); - Changes in reimbursement schemes (e.g., capitation, prospective payment, salaried providers)

## Methodology

Our review involved an exhaustive search strategy of the Medline, Cochrane (including, quite importantly, the Cochrane Effective Practice and Organisation of Care (EPOC) Review Group registry), and other relevant databases, as well as hand searches of articles and bibliographies. We employed standard inclusion/exclusion criteria, definitions and protocols; re-review of exclusion decisions by study personnel, and independent abstractions by two reviewers, with conflicts resolved by consensus. In assessing the quality of a given study, we used a hierarchy of design (Level 1 studies were randomized controlled trials, Level 2 were controlled before-after studies, interrupted time series, and quasi randomized trials, and so on), and used the highest quality evidence available to assess the value of each QI strategy. We acknowledge that much of the important work in quality improvement is performed “in the trenches,” by front-line workers taking advantage of available resources to answer important, practical questions using simple designs (e.g., uncontrolled before-after studies). However, in a report of this type, we felt it important to strive to find and analyze studies whose research methodologies were likeliest to give scientifically correct answers. In analyzing our results, we performed quantitative analysis (including the calculation of summary effects, adjustment for unit of analysis errors, and meta-regression analysis) when enough studies with similar outcomes were available, and studies were sufficiently homogeneous in both design and population.

Hypertension has been defined as systolic blood pressure (SBP) greater than 140 mmHg and diastolic blood pressure (DBP) greater than 90 mmHg ( > 140/90), with normal blood pressure set at < 120/80. It is estimated that 58.4 million Americans have hypertension, making it the most common primary diagnosis in the United States. Hypertension is a major risk factor for cardiovascular disease, and high quality evidence (codified in the periodic reports of the Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure (JNC)) supports the premise that treatment of hypertension, most commonly with drug therapy, reduces such risks. Even small reductions can have profound effects: a 1990 meta-analysis of 14 randomized treatment trials found that lowering DBP 5–6 mmHg reduced stroke rates by 42 percent. The recently issued JNC 7 has emphasized the efficacy of diuretics, recommending them as initial therapy for most patients, either alone or in combination with one of the other classes of agents (ACE inhibitors, angiotensin receptor antagonists, β-adrenergic receptor antagonists, calcium channel antagonists) demonstrated to be beneficial in randomized trials.

Despite this extraordinary clinical knowledge base and the link between treatment and outcomes, there is a profound quality gap in the management of hypertension. In the U.S. in 1999-2000, 69 percent of people with hypertension were aware of their condition, but only 58 percent of hypertensives were receiving treatment. Moreover, it is estimated that only 31 percent of known hypertensives in the United States have well-controlled blood pressure. Among the possible reasons for this gap are the asymptomatic nature of hypertension, the necessity of lifelong management for most patients, the frequently changing therapeutic recommendations, and the importance of individualizing and titrating treatment.

We focused on the quality gap in patients with primary hypertension (also called “essential” hypertension) in non-pregnant adults. This population makes up more than 90 percent of all patients with hypertension. Our quality improvement targets were primarily measures of blood pressure screening (i.e., strategies to increase the percentage of patients with high blood pressure who are aware of their condition) and control (i.e., fraction of patients with known hypertension whose blood pressure is within the range recommended by the JNC and others). We captured outcome measures (such as mortality) when they were reported, but they usually were not. We also considered measures of both provider (e.g., adherence to specific medication recommendations) and patient (e.g., attending followup appointment) adherence to recommendations.

From our original sample of 3,071 potentially relevant articles, a total of 359 merited full-text review. Of these, 110 merited full abstraction. After excluding those consisting solely of a patient education strategy (to be reviewed separately in a subsequent volume in the Series), our sample consisted of 63 articles reporting a total of 82 comparisons of QI intervention to a control group.

## Findings

Studies of hypertension identification and initial followup were too heterogeneous to be analyzed quantitatively. The majority were clinic-based (though a few were offered at work sites), and the most common strategies were patient and/or provider reminders. They generally showed positive results; several studies found that patients were more likely to know their blood pressure or attend clinic visits after receiving reminders. Frequently used strategies included patient reminder letters, computer identification of patients with historically poor follow-up (with computer-generated reminders to these patients), and the addition of a health promotion nurse to identify and followup with high-risk patients.

The evidence-base behind QI strategies designed to improve blood pressure control was more robust, and its results were generally positive. Across all studies (of a variety of strategies), the median reduction in SBP was 4.5 mmHg (IQ range: 1.5, 11.0), and median reduction in DBP was 2.1 mmHg (IQ range: -0.2, 5.0). Overall, the median increase in the proportion of patients in target SBP range and target DBP range in these comparisons was 16.2 percent (IQ range: 10.3, 32.2), and 6.0 percent (IQ range: 1.5, 17.5), respectively. Note that the QI strategies had a somewhat larger effect on SBP than on DBP; the latter was previously considered the more important target, but recent research has confirmed the importance of treating systolic hypertension.

Our findings suggest that quality improvement strategies, in general, appear to be associated with improved detection and control of hypertension. Since most studies included more than one QI strategy (although, unlike in diabetes, multiple interventions did not appear to be associated with greater effect sizes in hypertension), it is not possible to discern with complete confidence which QI strategies have the greatest effects. All of the strategies assessed—organizational change, patient education in combination with several other QI strategies, provider education, facilitated relay of clinical data, audit and feedback, promotion of self-management, provider reminders, patient reminders, and financial incentives—may be beneficial under some circumstances, and in varying combinations. Studies that involved organizational change appeared to have the largest effects on outcomes, although there were some methodologic concerns about confounding due to study size. Organizational change may work, at times, because the change meshes well with existing structures and resources in a given institution; the applicability of these changes to other settings may be limited. Moreover, a given organizational change (i.e., the hiring of a nonphysician provider to contact patients) may simply be a marker for high levels of administrative support or funding, further limiting the applicability of the change itself to other settings.

Like organizational change, studies including patient education as part of the QI strategy also appeared to have relatively large effects, but unfortunately these results also are confounded by study size.

Studies that focused on improving provider adherence with recommendations for the management of hypertension had less effect (median effects ranged from a 1.3 percent reduction to 3.3 percent improvement in adherence across the QI strategies). There are probably several reasons for this limited impact, including past controversies in the medical literature over treatment goals and therapeutic options, rapidly changing recommendations (best evidenced by a new JNC report every few years), practice “inertia,” and environmental influences such as time pressures, incentive structures, and resource constraints.

## Conclusions

Despite the importance and prevalence of both diabetes and hypertension, and the richness of their clinical literatures, studies that would help patients, providers, and policymakers choose how best to close their quality gaps are somewhat confusing. For each entity, certain strategies (such as the use of multifaceted interventions, and perhaps disease management in diabetes, and the adoption of organizational change in hypertension) appear to be more effective than others. Yet, even in these areas, problems with publication bias, co-interventions, and secular trends make sweeping conclusions hazardous. Our review provides a huge collection of research data for the interested reader to dissect; undoubtedly, there is information that will be directly applicable to a given clinical situation or location. At the synthesis level, however, the most striking finding from these systematic reviews is the need for additional, high quality research to clarify how best to translate research into practice for these common, highly morbid disorders.