# Conclusions

Our review found that QI strategies result in increased detection of hypertension, and improved management, as measured by blood pressure. However, we found only small changes in provider and patient adherence due to QI interventions. Studies that included organizational change and patient education reported greater improvements in blood pressure control than did studies without these strategies, but the evidence is not sufficient to definitively establish the superiority of any individual QI strategy relative to others. The reported improvements in blood pressure control were smaller in larger studies than in smaller studies, raising a concern that our overall measures of the effectiveness of QI strategies may be overestimated because of publication bias.

Closing the quality gap will take sustained effort from the many parties with an interest in detection and management of hypertension. Our review documents the varied approaches to QI for hypertension that have received careful evaluation. The summary analyses provide a high level overview of these QI interventions. Perhaps as importantly, the details of individual studies offer a resource that may help guide further QI implementation and evaluation.

Despite the many studies documented here, the evidence about the usefulness of QI strategies in hypertension care is incomplete. There is a strong need for further and more detailed evaluation. Future studies will be more useful if they are designed rigorously, describe QI interventions carefully, and provide information about the organizational setting in which they are performed.

Each new attempt to close the quality gap in hypertension will likely need to be tailored to specific circumstances. ^42^ We hope this report provides a useful starting point for individuals and organizations that are trying to improve the detection and management of hypertension, and for investigators attempting to further the field of quality improvement.

“Some observers have suggested that the answer to this problem is to produce a seventh version of the Joint National Committee Report on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (JNC). Others counsel that what we need is not a new guideline but rather the will to implement what we already have, which is extensive. While JNC has been a valuable tool, it cannot be the only answer to controlling hypertension because it is an education tool, not an action tool. The application of the JNC... is what matters.”

— Claude Lenfant, Director, NHLBI, from Reflections on Hypertension Control Rates. A Message From the Director of the National Heart, Lung, and Blood Institute ^191^