# Discussion

Hypertension is highly prevalent in the general population, and carries with it serious cardiovascular morbidity and mortality risks. The implementation of quality improvement strategies aimed at detection and management of this disease has the potential to improve the health of millions of Americans.

Our review of more than 3000 titles, which identified 82 core comparisons relating to the general areas of disease screening and management of hypertension, confirms some previous findings and extends them, with the addition of recent studies and further analyses. ^50,^ ^52^ Of the studies meeting our inclusion criteria, one-third were published in the past five years (1998-2003). The main questions we sought to answer were which QI strategies could most effectively result in improved detection of hypertension, blood pressure control, and improved patient and provider adherence. Our findings suggest that quality improvement strategies in general appear to be associated with improved detection and control of hypertension. Since most studies included more than one QI strategy, it is not possible to discern with complete confidence which QI strategies have the greatest effects. All of the strategies assessed—organizational change, patient education in combination with several other QI strategies, provider education, facilitated relay of clinical data, audit and feedback, promotion of self-management, provider reminders, patient reminders, and financial incentives—may be beneficial under some circumstances, and in varying combinations. Studies with organizational change had the largest effect on outcomes in general, a finding which persisted regardless of study design (e.g., RCTs versus CBAs or quasi-RCTs). However, after analysis of study sample size, which raised a concern about publication bias, these findings are less convincing. Studies including patient education as part of the QI strategy also appeared to have relatively larger effects, but these results are also confounded by study size, and are additionally uncertain because studies examining patient education alone were not reviewed in this report, but rather set aside for a subsequent review in the series. Finally, studies with audit and feedback did not show as much improvement in outcomes as studies without this strategy, but there were relatively few studies reporting multiple outcomes that included this strategy. Although conclusions about specific strategies require caveats, QI strategies in general appear beneficial for closing the quality gap in hypertension.

## Which QI Strategies Improve Screening for Hypertension?

Increasing the percentage of individuals screened for hypertension is a critical national health goal. In general, most interventions led to some improvement in the intervention group, such as an increased number of individuals screened, an increased number of individuals who knew whether or not their blood pressure was elevated, or an increase in those identified as hypertensive who received appropriate followup. No single QI strategy had enough screening studies to provide pooled results, and therefore discussion of each strategy independently is not feasible.

Screening interventions were generally conducted in one of two environments: in the community (outside of medical settings), or at medical clinics. In the community, interventions at work sites appeared to be effective. ^138,^ ^166^ In the clinic, several strategies appeared effective. These include patient reminder letters, computer identification of patients with historically poor followup along with computer-generation of provider reminders about these patients, and the addition of a health promotion nurse to identify and followup with high-risk patients (Table 5). Because there were few studies of screening (10), and because of the heterogeneity of the outcomes measured, we were unable to conduct quantitative analyses of the impact of screening.^†^

† The MRFIT and the HDFP trials do not appear in our analysis of screening because these studies performed screening solely to identify individuals to be enrolled in the disease management portion of those studies, not as an outcome related to the intervention. We report results from these studies in Appendix F. Another large screening study, the North Karelia Project,169 is omitted from our systematic review because it was conducted before our inclusion date of 1980.

## Which QI Strategies are Most Effective at Ensuring that Blood Pressure Goals are Achieved and Maintained?

Most of the quality improvement strategies we assessed had a positive impact on at least one of the blood pressure outcomes measured. The only outcome measures reported frequently enough for data analysis were reductions in SBP and DBP, and achieving SBP and DBP in target ranges. Most studies used more than one QI strategy. Thus, the following results, presented by type of QI strategy, must be interpreted with caution.

With this important caveat, the largest effect sizes for SBP and DBP reductions were observed in the strategies of organizational change, provider reminders (either alone or in combination with other QI strategies), and patient education (reviewed only in combination with other strategies, and often including organizational change).

For achieving SBP and DBP in target range, most of the strategies appeared to be effective, but were often used in combination. The strategies with larger effects include organizational change, patient education, promotion of self-management, and facilitated relay of clinical data (usually in combination with organizational change as well as other strategies). Audit and feedback, patient reminders, and financial incentives showed relatively more modest effects, although there were generally fewer studies of these interventions.

## Effect of Specific QI Strategies on Achieving And Maintaining BP Goals

Studies that included organizational change tended to report larger effects on blood pressure outcomes than studies that did not include this QI strategy. Organizational change strategies are varied, and some substrategies of organizational change may work better than others. Case management and team staffing changes often appeared effective. The vast majority of studies of organizational change in hypertension included changes in team members' roles, additions of staff, or other re-organization of work flow for caring for hypertensive patients.

There are many possible explanations for the success of organizational change with respect to achieving blood pressure control. Organizational change typically requires administrative support, which may itself be an important factor in the success of a QI strategy. Many studies of organizational change include designation of specific staff to address hypertension, which may represent either an increase in staffing or a re-allocation of staff effort to hypertension; in either case, it could represent an absolute increase in health professional time allocated to hypertension. However, it is also possible that an organizational change could achieve an effective increase in attention to hypertension by re-designing work flow without increasing the overall staffing devoted to hypertension management. Most studies did not report information that would allow us to make this distinction. The finding of the effect of organizational change is consistent with a report from an observational study of the Veterans Affairs Health Care System, which found moderate improvements in rates of blood pressure control after implementation of systemwide reengineering. ^170,^ ^171^ A randomized clinical trial published too recently to be included in our analysis confirms the major impact that organizational change may exert on blood pressure outcomes. Among 309 inner city African American men, comprehensive interventions in the community, by a multidisciplinary team, resulted in 44 percent of the subjects having controlled blood pressure (compared with 17 percent at baseline). ^172^

Patient education appeared to be a successful strategy for improving blood pressure control, but we evaluated it only when it was used in conjunction with other QI strategies. Therefore, the impact of patient education per se may be overestimated in the studies we included. Our findings that patient education may be effective in improving blood pressure comport with those of a previous meta-analysis. ^50^ However, although patient education produced the largest reduction in blood pressure of the various methods studied in one systematic review, ^52^ one particular study (which combined a number of interventions along with patient education) accounted for most of this finding. Our analysis does not allow for an evaluation of the efficacy of patient education as a sole QI strategy for blood pressure control.

Our findings on provider education differ from the negative findings in one previous, smaller review of physician education interventions in the management of hypertension. ^68^ However, in our review, provider education was usually accompanied by other QI strategies, so the effect on outcomes attributable to provider education or its substrategies is not known.

Other strategies, such as provider reminders, promotion of patient self-management, and audit and feedback, all appear to have relatively modest effects, and, when positive, were often coupled with other strategies as part of a multifaceted intervention. Our findings regarding promotion of patient self-management on BP control are consistent with those of a previous meta-analysis, and a systematic review. ^50,^ ^52^

Our findings regarding audit and feedback are consistent with the conclusions of a recent systematic review of that strategy, which states: “when it is effective, the effects are generally small to moderate.” ^173^ The studies of audit and feedback in hypertension are a small subset of the studies in this review, and highlight the difficulty of interpreting results of specific QI strategies for a selected clinical area. While a strategy may be more or less effective in one clinical area compared with another, the ability to detect such differences, or lack thereof, are hampered by the limited number of studies for any particular strategy, as well as the confounding due to multifaceted interventions and study quality.

## Which QI Strategies Improve Provider Adherence with Recommendations for Management of Hypertension?

Surprisingly, the median increase in percentage of providers adhering to recommendations was relatively small, or even negative, for all QI strategies (median effects ranged from a 1.3 percent reduction to 3.3 percent improvement in adherence across the QI strategies). Only limited conclusions can be drawn, because we found mixed results among the 10 comparisons with data on this outcome, and there was significant overlap of studies across QI strategies. We also note that most of the studies reporting provider adherence outcomes are different from the studies that report blood pressure outcomes. Provider adherence included adherence with recommended medications, as well as adherence with other recommended practices, such as appropriately ordered laboratory tests. It is important to recognize that although guidelines recommending specific antihypertensives for treatment of particular comorbidities are evidence based, ^1^ there was not always an evidence base supporting the adherence outcomes we analyzed in the studies we reviewed.

There are a number of possible contributing factors that may explain the finding of the limited impact of QI strategies on provider adherence to recommended practice, if in fact this is a true effect. Past controversies in the medical literature about the relative importance of DBP versus SBP, as well as frequent change to overall targets for hypertension control, may have led to some provider confusion about appropriate targets for BP control. The large number of drugs available to treat hypertension, and the promotion of certain drugs for certain classes of patients, may also lead to some provider confusion. It is also possible that some providers do not agree with the guideline recommendations. For example, early trials using the thiazide class of diuretics used larger doses that were commonly associated with hypokalemia, a potentially serious problem. It is now known that much smaller doses, only rarely associated with hypokalemia, are effective in most patients; however, providers may still be reluctant to use them due to prior adverse effects on their patients. Because medical decision making is prone to “availability bias,” a single negative outcome may be remembered vividly, and may exert undue impact on future decisions. ^174^

A systematic review examining barriers to physician adherence to clinical practice guidelines identified a number of potential barriers (e.g., lack of awareness, inability to reconcile patient preferences with guideline recommendations, lack of resources). ^175^ This review noted that studies on improving physician guideline adherence may not be applicable across specialties or practice settings, as barriers in one setting may not be present in another. ^175^ Practice “inertia” may also be a barrier. The theme of “inertia” of previous practice has been attributed to at least three problems: overestimation of care provided; use of “soft” reasons to avoid intensifying therapy; and lack of education, training, and practice organization aimed at achieving therapeutic goals. ^176^

The apparently small effect of QI strategies on provider adherence outcomes is a finding that deserves future attention, because of the importance of provider behavior in attaining goals of improved hypertension outcomes. As described in a systematic review from the National Health Service in the United Kingdom, ^52^ a greater health gain could theoretically be obtained by improving professional standards of detection of hypertension and the proportion of patients with hypertension receiving treatment, as compared with the expected health gains from improvements in patient adherence to treatment. Although the applicability of these data to the United States may be limited, the analysis serves to emphasize the key role of provider adherence in improving hypertension outcomes.

## Which QI Strategies Improve Patient Adherence with Treatment?

Use of patient education (in combination with other strategies), organizational change, facilitated relay of clinical data, and patient self-management as part of a QI strategy may have all improved patient adherence. However, relatively few studies assessed this outcome, and thus the evidence base is limited. Our findings that patient education may be effective in improving patient adherence are consistent with those of a previous meta-analysis, which found that patient education appeared to be effective in improving adherence with medications, and improving adherence with appointments. ^50^ We note again that the effect of patient education may be overestimated in the included studies, since patient education was never analyzed when it appeared as the sole component of an intervention, only when it was considered in combination with at least one other QI strategy.

## Importance of Organizational Setting for Quality Improvement Interventions

Implementation of a QI strategy is essentially an attempt to change human behavior, either of health professionals or of patients. In studies of QI strategies, the organizational context of the study is very likely to have an impact on the effectiveness of the QI strategy. For example, if a QI strategy is implemented in a health care system despite objections from most of the professional staff, one would expect the likelihood of success to be lower than if the implementation enjoys the support of the staff, since it is staff who must carry out the strategy. Moreover, whether a given organizational strategy happens to mesh with existing features of an organization (such as its values or staffing patterns) may be a more important determinant of success than the QI strategy per se.

We also recognize that over the period of time—more than twenty years—of the studies we have included, there have been many changes in health care delivery systems that may affect the organizational context for QI implementation. We were not able in this evidence review to account for the impact of organizational context, because little information about it is presented in the published papers. We do report the setting of each study (see Table 1 and Appendix F), and readers who are contemplating implementation of a QI program may consider the similarity of the reported settings to their own, and the feasibility of implementation of the strategy in their own context. We also provide the actual results of each of the studies meeting the standards for inclusion, so that readers may consider the actual results of strategies that they may want to replicate.

### Study Design Effects

Studies that are less methodologically rigorous may present more impressive-appearing findings, because less care was taken to correct for potential biases. Our analysis suggests that methodologic features affected some findings for QI strategies for hypertension. We found a fairly striking correlation between study size and effect size, particularly for SBP and DBP outcomes: larger studies reported less impressive reductions in blood pressures. This pattern did not hold for each individual QI strategy, but some individual strategies were used in very few studies. In further exploring possible confounding of study size with other study design features for the SBP and DBP outcomes, we found that studies in which the unit of randomization was the same as the unit of analysis appeared to account for the correlations between study size and effect size.

Our findings regarding the relationship between other study design features and effect size were mixed. For example, there was no clear relationship of RCT-study-design with effect size; findings differed for different outcomes.

### Effect of Number of QI Strategies

We did not find a consistent pattern of improved outcomes with an increased number of QI strategies, and in fact, found that single QI strategy studies had larger effects compared with multifaceted QI strategies. However, our findings should be interpreted with caution because of the small number of studies, the large inter-quartile ranges, and possible confounding since most of the single QI strategies involved organizational change. Prior reviews have reached conflicting conclusions about the relative impact of adding more QI strategies, irrespective of their content. ^45,^ ^83,^ ^173,^ ^177^

### Additional Comments

Multiple risk factors. Many of the quality improvement strategies targeted hypertension as one of several risk factors to be controlled (e.g., for cardiovascular disease risk reduction). This confounded our ability to draw conclusions about the effect the specific QI strategy component had on hypertension, as distinct from the other risk factors.

Sources of variation in measurements of blood pressure. Many different blood pressure thresholds have been used to assess quality of care, ^178^ including percentage of patients with blood pressure exceeding a particular control threshold. Guidelines defining control have changed over time. This situation has implications with respect to the conclusions that can be drawn from studies reporting interventions that showed positive effects on achieving blood pressure control. For instance, some QI studies, particularly older studies, used control thresholds such as 160/95, whereas many recent studies define the control threshold at 140/90. Some hypertension quality of care studies used mean blood pressures for a particular patient over a number of visits, to determine whether they met control thresholds, whereas others used single visit blood pressure readings. The use of varied definitions of control, and different measurement techniques to determine control, may result in different judgments of quality of care. ^178^

Effect of QI interventions on mortality. Few studies reported mortality measures, perhaps because most quality improvement studies did not have a long enough study period or large enough study populations. For the six studies that did report mortality data, only two reported mortality as a primary outcome measure. The MRFIT study reported a lower mortality rate at ten-year followup that was not statistically significant. ^105^ The HDFP study, however, showed reduced mortality of 16.9 percent with stepped care. ^20^ It is not possible to state what portion of the mortality benefit was due to the special components of the intervention that might be considered QI strategies, and what portion was due to the choices of drug therapy or other factors; however, overall, the application of the strategy was effective. With refinements to drug therapy since that time, for example the recognition that lower dose thiazide diuretics achieve reduction of blood pressure with fewer episodes of hypokalemia, it is possible that application of QI strategies such as those used in the stepped care program would be even more effective today. On the other hand, at the time that the HDFP study was conducted, the importance of treating systolic hypertension was not well-recognized, and the overall targets for BP control were higher. It is possible that application of the same strategies today would appear less effective in comparison to usual care, because current usual care includes treatments that were not then in use.

Relationship of reduction in average BP with improvements in percent of patients achieving BP in target range. For some QI strategies, the median effect on SBP or DBP does not correlate consistently with the median effect on improving the proportion of patients in SBP or DBP target range. For example, for some strategies, the decrease in BP was small, but resulted in a substantial increase in the percentage of patients in a target range, and vice versa. The relationship of reduction in the average BP with improvement in the percent of patients achieving BP in target range depends on several factors, including the baseline average BP, the variance in the BPs, and the baseline percent of patients in target range. Depending on the distribution of blood pressure and the range chosen as acceptable, a small change in mean BP can result in either small or large changes in the percentage of patients in the acceptable range. For a more detailed explanation, see Appendix I.

Potential benefits of clinical information systems. Studies that used a clinical information system had mixed effects, including some negative effects, in blood pressure outcomes and provider adherence. In light of the high expectations for information technology to improve health care, our findings from the studies published to date are disappointing. The potential for information technology to improve the quality of health care has been described by the Institute of Medicine as “enormous.” ^179^ A systematic review by Balas, et al, of 98 randomized clinical trials of computerized information services showed that about 75 percent reported substantial improvements. ^180,^ ^181^ Considerable evidence, summarized in systematic reviews, shows that automated reminder systems improve provider adherence to clinical practice guidelines. ^179,^ ^180,^ ^182,^ ^183^ Another systematic review of 68 controlled clinical trials assessing the effects of computer-based clinical decision support systems (CDSSs) on physician performance and patient outcomes found enhanced clinical performance for drug dosing, preventive care, and other aspects of medical care, but insufficient evidence regarding improvement in patient outcomes. ^184^ A 1998 systematic review of the use of computers in the management of hypertension showed that computers appeared to have a favorable effect on the uptake and followup of patients in hypertension management; however, the effect on blood pressure control was less conclusive. ^145^

We believe that it would be premature to draw conclusions based on the overall effects for clinical information systems. In many studies, the information systems used were only to identify eligible patients. Many medical centers and clinics are only now adopting electronic medical record systems that will permit smooth integration of clinical decision support with clinician work flow. In many cases, information technology that has been developed in academic research centers has yet to be tested in large clinical trials. Decades of research have produced an infrastructure in medical informatics to support health care research and quality. ^185^ With further development of the infrastructure, new clinical trials will undoubtedly be conducted, and may yield different results from the few studies published to date.

### Limitations in Interpretation of the Data

Conclusions based on pooled data are tentative, and must be interpreted cautiously. Each quality improvement study was conducted within a particular set of contexts, including practice type, era of guideline recommendations, local attitudes toward guideline implementation, and other potentially confounding factors. Nevertheless, although hypertension guidelines have changed over time, studies using older guidelines can provide useful evidence about whether or not quality improvement strategies work.

As with all systematic reviews, there is the possibility of missing relevant studies. For example, in this instance, studies that focus on a particular quality improvement strategy for broad application may have included hypertension, without specifying its inclusion in the title, abstract or subject headings, and would therefore be missed by our search strategy. ^186^

### Recommendations for Future Research on Quality Improvement Implementations

Based on our review of published reports of QI strategies for hypertension, we offer several suggestions for future QI implementation research:

Clustering issues. The impact of the randomization choice should be discussed in published studies, and steps taken to account appropriately for clustering in the data analysis. Numbers of clusters and descriptive statistics of numbers of patients per cluster should be reported. An updated Consolidated Standards of Reporting Trials (CONSORT) statement specifically addressing cluster-randomized trials is in press. ^187^ – ^189^

Blinding in measurement of study outcome. Providers performing clinical examinations may be unconsciously biased by prior expectation of a particular result. ^190^ In a study in which the provider who measures the patient's BP knows that a patient is receiving a QI intervention, the outcome measure may be unconsciously biased by an expectation of improvement. When the provider is also the individual who delivers the QI intervention, the prior expectation of benefit may be even more powerful, and the unconscious bias greater. Reports should specify whether the outcomes were measured by individuals who were blinded to the intervention status.

Pre- and post-intervention measures for both intervention and control group. Baseline differences between the intervention and control groups can have major effects on outcome measures. Reports should report both pre- and post-intervention measurements for both control and intervention groups, and should take account of baseline differences in statistical analyses, for example, by comparing change from baseline.

Organizational factors affecting QI interventions. Aspects of the organizational structure and setting of the providers' clinical practice may affect incentives to follow guidelines. For example, providers employed in a health care system would be expected to respond differently to recommended guidelines when a criterion of their performance standard includes adherence to such guidelines, as compared with independent providers, who may electively determine whether or not to implement guidelines. As another example, when guidelines are recommended by a health insurance plan, adherence among providers with a large proportion of patients enrolled in that particular plan may differ as compared with providers whose patients are enrolled in many different plans. Further examples include extent of administrative support for the QI implementation. There is not, however, a clear consensus about how to define or measure such organizational factors. Possible factors to report in future studies include, among others:

- Descriptive information about organizational arrangements of providers in the study, for example, status as employees or independent practitioners.
- Descriptions of time constraints on clinical practice.
- Descriptive information about incentives for providers to follow recommended guidelines, for example, use of rates of guideline adherence in credentialing, performance review, or other processes.
- Description of the types and extent of administrative support and involvement of local clinical leadership; for instance, reports could include whether the QI strategy was implemented with research funds, administrative funds, or both, description of administrative support, and, if relevant, how this support was communicated to staff.

Number of QI activities concurrently implemented. The number of distinct QI implementations within a health care clinic or system may affect responses of both providers and patients. On one hand, providers or patients who receive many QI interventions may become less attentive to the interventions. On the other hand, providers or patients who become accustomed to QI interventions may incorporate a new approach to management of disease and may be more likely to adhere to guidelines. In order to evaluate the impact of such effects so that such questions may be addressed in future research, possible factors to report include:

- Number of programs in different areas being implemented concurrently in the study setting in which the QI strategy is being evaluated
- Information on the organizational culture regarding attitudes toward guideline implementation and QI strategies

Adverse effects of the QI intervention. As with all effective treatments, QI implementations have the potential for unintended adverse consequences. To date, these are rarely reported. Additionally, there is as yet no clear consensus as to methods for attributing adverse effects to a particular QI implementation, or which potential adverse effects to monitor and report. Because of this lack of consensus, studies of QI implementations rarely obtain information that would allow reporting of these factors. Candidate factors to consider include:

- Adverse effects on individual patients that are potentially due to aggressive implementation of particular guideline recommendations, for example, for hypertension, rates of syncope, falls, and morbidity related to falls (e.g., hip fracture) compared between study arms. Such factors might be particularly important to monitor in QI implementations that include strong incentives to providers to achieve certain targets for BP; and
- Adverse effects on populations of patients (e.g., the impact of guideline implementation for one disease on rates of guideline adherence for other diseases). Studies conducted in health care systems with clinical databases may be able to monitor database indicators of such rates. Another example might be the potential adverse effect of shifting staff resources from one area to another. It is well-recognized in cost-effectiveness analysis that it is essential to consider all the costs associated with an intervention, not merely the immediate costs of providing the intervention initially. Similarly, it may be important to consider the effect on an entire health care system of shifting resources within the system.

Future QI reviews should consider adopting the CONSORT Statement, which provides a checklist of items to report in publications of randomized controlled trials. ^187^ The Statement is intended to improve the reporting of trials, to enable readers to understand how the trial was conducted, and to assess the validity of the results.