# Results

## Search Yield and Results of Literature Review Process

Figure 1 depicts the article search and review process with the results at each step. From a literature search that resulted in 3070 citations, 110 articles merited full abstraction (Figure 1). Of these, 47 consisted solely of a patient education strategy (Appendix E), and are not reviewed here, as this topic will be reported in a future volume of this series. Our study sample consists of 63 articles ^73,^ ^105^ – ^165^ reporting a total of 82 comparisons of QI strategies (Appendix F). Forty-eight studies are randomized controlled trials (reporting on 64 different comparisons), six are quasi-randomized controlled studies (reporting on seven different comparisons), and nine are controlled before-after studies (reporting on 11 different comparisons) (see Table 1 and Appendix F).

Table 1 Included studies

Setting | Study Period | Study Design | QI Strategies | Outcomes
| (Duration/months) | (Sample Size) | Employed* | Reported ^†^ **
22 clinics | 1973-1982 | RCT | Pt Ed, Org Change | Dz: SBP, DBP
(18 US cities) ^1^ | (99) | (8012 patients)
2 hospital-based family medicine centers | 1983-1987 | CBA | Pt Remind, Prvdr Ed, Audit & Fdbck, Org Change | DzID: BP Meas
(Canada) ^2^ | (60) | (13 providers, 817 patients)
Cleveland Veterans' Affairs Medical Center Ambulatory Clinic | 1992 | Quasi-RCT | Prvdr Ed, Facil Relay, Audit & Fdbck | Prvdr Adhere: Med Rec
(Cleveland, OH) ^3^ | (2) | (2157 patients)
General practice and hospital-based ambulatory clinic | 1994-1996 | CBA | Prvdr Ed | Dz: SBP, DBP, BP Range
(Italy) ^4^ | (36) | (121 providers, 2253 patients) | | Prvdr Adhere: Med Rec
| | | | Pt Adhere: Meds
Kenmore Center of the Harvard Community Health Plan | 1975-1977 | RCT | Prvdr Remind, Info System | DzID: BP Elev FU
(Boston, MA) ^5^ | (21) | (115 patients) | | Dz: Other
| | | | Prvdr Adhere: Check BP
34 family practices | 1978-1982 | RCT | Pt Ed, Pt Remind, Prvdr Remind, Org Change | DzID: Other
(Canada) ^6^ | (60) | (34 practices, 32124 patients) | | Dz: SBP, DBP
| | | | Pt Adhere: Meds
1 ambulatory practice center, Temple University School of Medicine | — | RCT | Pt Ed, Self-Mx, Pt Remind | Dz: DBP, BP Range
(Philadelphia, PA) ^7^ | (3) | (171 patients) | | Pt Adhere: Meds
20 community pharmacy sites | 1997-1998 | Quasi-RCT | Facil Relay, Org Change | Dz: BP Range
(England) ^8^ | (7) | (25 pharmacies, 282 patients) | | Pt Adhere: Meds
1 primary care outpatient teaching clinic, The Queen's Medical Center | — | Quasi-RCT | Pt Ed, Prvdr Remind, Facil Relay, Org Change | Dz: SBP, DBP, BP Range
(Honolulu, HI) ^9^ | (6) | (100 patients)
1 hypertension clinic (unspecified US city) ^10^ | — | RCT | Pt Ed, Facil Relay, Org Change | Dz: SBP, DBP, BP Range
| (12) | (197 patients) | | Prvdr Adhere: Med Rec
6 community sites | 1974-1982 | RCT | Org Change, Financial | DzID: BP Elev, BP Elev FU
(Seattle, WA; Dayton, OH; Fitchburg or Franklin County, MA; and Charleston or Georgetown County, SC) ^11^ | (98) | (3958 patients) | | Dz: SBP, DBP, BP Range
| | | | Prvdr Adhere: Med Rec, Eval HTN, Pt Counsel
| | | | Pt Adhere: Other
19 general practices (Scotland) ^12^ | — | RCT | Pt Ed, Prvdr Ed, Org Change | Dz: BP Range
| (12) | (1343 patients)
2 group medical practices | — | RCT | Pt Ed, Prvdr Ed, Facil Relay, Org Change, Info System | Dz: SBP, DBP, BP Range
(Taylorville, IL) ^13^ | (6) | (55 patients) | | Pt Adhere: Meds
3 specialist hypertension clinics | — | CBA | Pt Ed, Pt Remind, Org Change | Dz: SBP, DBP, BP Range
(Scotland) ^14^ | (48) | (396 patients)
Patient's residence/primary care clinic ^15^ | — | RCT | Pt Ed, Self-Mx, Org Change | Dz: BP Range
| (24) | (218 patients)
2 manufacturing plants | 1985-1988 | RCT | Pt Ed, Org Change | Dz: BP Range
(unspecified cities, MI) ^16^ | (36) | (2 sites, 4341 patients)
Urban university-affiliated internal medicine clinic | — | Quasi-RCT | Pt Ed, Self-Mx, Facil Relay, Org Change | Dz: SBP, DBP, BP Range
(unspecified US city) ^17^ | (5) | (80 patients)
62 physician practice groups | — | RCT | Prvdr Ed, Prvdr Remind | Dz: SBP, DBP, BP Range
(Canada) ^18^ | (12) | (62 practices, 198 patients) | | Prvdr Adhere: Check BP
| | | | Pt Adhere: Meds
4 Ford Motor Company manufacturing plants | 1978-1981 | RCT | Pt Ed, Org Change | DzID: BP Meas, BP Elev, BP Elev FU
(Southeastern Michigan) ^19^ | (36) | ( 4 worksites, 11196 patients) | | Dz: BP Range
HMO family practice clinic, Group Health Cooperative of Puget Sound | 1986 | CBA | Prvdr Remind, Org Change, Info System | Prvdr Adhere: Med Rec
(Seattle, WA) ^20^ | (9) | (8 providers, 326 patients)
4 communities | 1978-1983 | CBA | Pt Ed, Self-Mx, Prvdr Ed | DzID: BP Elev, BP Elev FU, BP Knew
( Northern California) ^21^ | (64) | ( 4 cities, 2364 patients) | | Dz: SBP, DBP, BP Range
29 greater Boston communities | — | RCT | Pt Ed, Self-Mx, Facil Relay, Info System | Dz: SBP, DBP
(Boston, MA) ^22^ | (6) | (301 patients) | | Pt Adhere: Meds
1 pharmacy site (Portugal) ^23^ | 2000 | RCT | Pt Ed, Pt Remind, Facil Relay, Org Change | Dz: SBP, DBP
| (6) | (100 patients)
Patient's residence | 1998-1999 | RCT | Pt Ed, Self-Mx, Prvdr Ed, Org Change, Info System | Dz: SBP, DBP, BP Range
(Mexico) ^24^ | (6) | (718 patients)
15 small group practices at 4 primary care clinics | 1993-1996 | RCT | Pt Ed, Prvdr Ed, Prvdr Remind, Facil Relay, Audit & Fdbck, Org Change, Info System | Dz: BP Range
(Seattle, WA) ^25^ | (30) | (78 providers) | | Prvdr Adhere: Med Rec
MDs from 7 counties | — | RCT | Prvdr Ed, Facil Relay, Audit & Fdbck, Info System | Dz: BP Range
(San Francisco area, CA) ^26^ | (12) | (82 providers) | | Prvdr Adhere: Med Rec, Target BP
29 health centers (Norway) ^27^ | — | RCT | Prvdr Ed, Audit & Fdbck, Info System | Dz: SBP, DBP
| (21) | (29 practices, 2239)
Community site, Johns Hopkins Hospital catchment area | — | RCT | Pt Ed, Self-Mx, Pt Remind, Org Change | Dz: SBP, DBP
(Maryland) ^28^ | (12) | (204 patients) | | Pt Adhere: Appt
General Medical Outpatient Clinic at Duke University Medical Center | — | CBA | Pt Ed, Pt Remind, Org Change | Dz: BP Range
(Durham, NC) ^29^ | (24) | (391 patients)
10 VA medical centers, 1 academic center | — | RCT | Pt Ed, Self-Mx, Pt Remind, Facil Relay | Dz: SBP, DBP
(unspecified US cities) ^30^ | (6) | (133 patients) | | Pt Adhere: Meds
17 primary care clinics | — | RCT | Prvdr Ed | Prvdr Adhere: Other
(Saskatchewan, Canada) ^31^ | (12) | (22 providers)
1 hypertension clinic, Aldermoor Health Centre | — | RCT | Org Change | Dz: BP Range
(Southhampton, UK) ^32^ | (12) | (36 patients)
5 outpatient general medicine practices of a university-based internal medicine training program | 1998-2000 | RCT | Audit & Fdbck | Prvdr Adhere: Eval HTN
(unspecified US city) ^33^ | (30) | (44 providers)
Worksites | 1977 | RCT | Org Change | Dz: DBP
(Toronto, Canada) ^34^ | (12) | (457 patients)
38 business locations | 1979 | RCT | Pt Ed, Self-Mx, Pt Remind, Facil Relay, Org Change | Dz: DBP, BP Range
(Toronto, Canada) ^35^ | (12) | (194 patients) | | Pt Adhere: Appt, Meds
1 industrial worksite | — | CBA | Org Change | DzID: BP Elev
(Cheboksary, USSR) ^36^ | (60) | (5563 patients)
50 family practices | — | RCT | Pt Remind, Facil Relay, Info System | Dz: BP Range
(Toronto, Canada) ^37^ | (16) | (60 providers, 2833 patients)
1 general medical clinic | — | RCT | Pt Ed, Self-Mx, Pt Remind, Org Change, Financial | Dz: SBP, DBP, BP Range
(unspecified city, GA) ^38^ | (12) | (103 patients)
4 family practices Ottawa Civic Hospital | 1985-1986 | RCT | Prvdr Remind, Info System | DzID: BP Meas, BP Elev
(Ottawa, Canada) ^39^ | (18) | (4247 families, 5744 patients)
Hypertension clinic | 1986-1989 | RCT | Pt Remind, Facil Relay, Org Change, Info System | Dz: SBP, DBP, BP Range
(UK) ^40^ | (48) | (831 patients) | | Prvdr Adhere: Check BP
Patient's residence | — | RCT | Pt Ed, Self-Mx, Org Change | Dz: SBP, DBP, BP Range
(unspecified city, CO) ^41^ | (6) | (36 patients) | | Pt Adhere: Meds
Patient's residence | — | RCT | Self-Mx, Facil Relay | Dz: SBP, DBP
(Oakland, CA) ^42^ | (12) | (204 patients)
27 general practices | 1996-1998 | Quasi-RCT | Prvdr Ed, Facil Relay, Info System | Dz: SBP, DBP
(New Zealand) ^43^ | (24) | (27 practices, 614 patients)
Health care centers | 1997-1998 | RCT | Prvdr Ed, Audit & Fdbck, Info System | Prvdr Adhere: Med Rec
(Sweden) ^44^ | (11) | (40 providers, 46000 patients)
2 pharmacy sites | 1993-1995 | RCT | Pt Ed, Facil Relay, Org Change | Dz: SBP, DBP, BP Range
(Chicago, IL; Kenosha, WI) ^45^ | (20) | (64 patients) | | Pt Adhere: Meds
University group general practice | 1992-1994 | RCT | Pt Ed, Prvdr Remind, Org Change | Dz: Other
(Australia) ^46^ | (19) | (97 patients)
Primary care practices | — | RCT | Prvdr Ed | Dz: Other
(Canada) ^47^ | (18) | (25 providers)
Hypertension clinic | 1974 | RCT | Pt Ed, Org Change | Dz: SBP, DBP
Cincinnati General Hospital | (6) | (100 patients) | | Pt Adhere: Appt, Meds
(Cincinnati, OH) ^48^
1 general practice | 1986-1988 | RCT | Pt Ed, Org Change, Info System | DzID: BP Meas
(London, UK) ^49^ | (36) | (3117 patients)
State University of New York Upstate Medical University primary care outpatient clinic | — | RCT | Self-Mx, Facil Relay, Info System | Dz: Other
(Syracuse, NY) ^50^ | (11 weeks) | (121 patients)
2 primary group practices, VA Medical Center | — | RCT | Prvdr Ed, Prvdr Remind | Dz: SBP, DBP, BP Range
(Richmond, VA) ^51^ | (—) | (2 practices, 320 patients) | | Prvdr Adhere: Med Rec
1 primary care clinic | — | RCT | Pt Ed, Self-Mx, Pt Remind | Dz: DBP, BP Range
(South Africa) ^52^ | (6) | (224 patients) | | Pt Adhere: Meds
Medicine clinic | — | RCT | Org Change | Dz: SBP, DBP, BP Range
University Hospitals Clinic, Ohio State University | (12) | (40 patients)
(Columbus, OH) ^53^
Multi-specialty group practice | 1981-1983 | CBA | Pt Remind, Audit & Fdbck, Org Change, Info System | Dz: BP Range
(Edgecombe county, North Carolina) ^54^ | (21) | (8 providers, 460 patients) | | Pt Adhere: Appt
4 Kaiser Permanente Medical Centers | 1986 | RCT | Pt Ed, Self-Mx, Pt Remind, Facil Relay | Dz: SBP, DBP, BP Range
(Alameda and Contra Costa counties, CA) ^55^ | (12) | (430 patients)
VA medical center walk-in screening clinic | 1979 | RCT | Pt Remind | DZID: BP Elev FU
(Durham, NC) ^56^ | (3.5) | (74 patients) | | Dz: DBP
| | | | Pt Adhere: Appt
1 hypertension clinic, VA Medical Center | — | RCT | Org Change | Dz: SBP, DBP, BP Range
(Philadelphia, PA) ^57^ | (6) | (56 patients) | | Pt Adhere: Meds
Kenmore Center Harvard Community Health Plan | — | Quasi-RCT | Facil Relay, Info System | Dz: BP Range
(Boston, MA) ^58^ | (15) | (16 providers) | | Prvdr Adhere: Eval HTN
Patient's residence | — | RCT | Pt Ed, Self-Mx | Dz: Other
(Ontario, Canada) ^59^ | (2) | (31 patients) | | Pt Adhere: Meds
Duke-Watts family medicine center | — | RCT | Facil Relay, Audit & Fdbck, Info System | Dz: SBP, DBP, BP Range
(Durham, NC) ^60^ | (11) | (41 providers, 250 patients)
14 communities | 1974-1979 | RCT | Pt Ed, Self-Mx, Org Change, Financial | Dz: SBP, DBP, BP Range
(various US cities) ^61^ | (60) | (10940 patients) | | Pt Adhere: Meds
Patient's residence ^62^ | — | RCT | Pt Ed, Self-Mx, Facil Relay, Org Change, Info System | Dz: SBP, DBP
(Detroit, MI) | (5) | (26 patients) | | Pt Adhere: Other
3 rural regions | 1974-1979 | CBA | Pt Ed, Prvdr Ed | DZID: BP Elev, BP Elev FU
(SE Minnesota) ^63^ | (72) | (3 regions, 740 patients) | | Dz: SBP, DBP, BP Range

* Audit & Fdbck— audit and feedback to provider; Facil Relay—facilitated relay of information to provider; Financial—financial incentives; Info System—clinical information system; Org Change—organizational change; Pt Ed—patient education; Pt Remind—patient reminder; Prvdr Ed—provider education; Prvdr Remind—provider reminder; Self-Mx—resource for patient self-management.

† Dz: Measure of disease control; SBP—systolic blood pressure; DBP—diastolic blood pressure; BP Range—patients with blood pressure within a certain range; Other.

DzID: Measure of disease identification; BP Elev—patients with elevated blood pressure; BP Elev FU—patients with elevated blood pressure receiving follow-up; BP Knew—patients who knew blood pressure was elevated; BP Meas—patients who had blood pressure measured; Other.

Prvdr Adhere: provider adherence with recommendations for management of hypertension; Check BP—guidelines for checking or recording blood pressure; Eval HTN—guidelines for evaluation of hypertension; Med Rec—specific medication recommendations; Pt Counsel—guidelines for patient counseling or delivering patient education; Target BP—guidelines of targets for blood pressure; Other.

Pt Adhere: Patient adherence with treatment; Appt—appointment compliance; Meds—medication compliance; Other.

** Not all outcomes reported in Table 1 had sufficient information to use in quantitative analysis.

The types of quality improvement strategies and substrategies assessed in the articles are shown in Tables 2a and 2b. Among individual strategies, organizational change (particularly team staffing changes) and patient education (in combination with other interventions) were most commonly utilized. Educational interventions for providers were common as well. Most articles described interventions consisting of more than one strategy; only 21 percent (17/82) described a single strategy (Table 3). The 82 comparisons reported 42 unique combinations of strategies, with most of these combinations occurring in only one or two comparisons (Table 4).

Table 2b Quality improvement sub-strategies

QI strategy | Randomized Controlled Trial | Non-Randomized Controlled Trial* | Total
CME^†^ | 9 publications ^10,^ ^12,^ ^13,^ ^26,^ ^27,^ ^31,^ ^44,^ ^47,^ ^68,^ ^69,^ ^74^ | 6 publications ^2,^ ^3,^ ^8,^ ^21,^ ^43,^ ^63,^ ^64,^ ^66^ | 15 publications
| (11 comparisons) | (8 comparisons) | (19 comparisons)
Educational outreach | 4 publications ^25,^ ^26,^ ^44,^ ^47,^ ^67,^ ^69^ | 2 publications ^3,^ ^21^ | 6 publications
| (6 comparisons) | (2 comparisons) | (8 comparisons)
Distribution of printed materials | 10 publications ^12,^ ^18,^ ^25^ – ^27,^ ^31,^ ^44,^ ^47,^ ^51,^ ^67^ – ^69,^ ^74^ | 3 publications ^2,^ ^3,^ ^21^ | 13 publications
| (13 comparisons) | (3 comparisons) | (16 comparisons)
Disease/Case management | 8 publications ^6,^ ^12,^ ^13,^ ^25,^ ^32,^ ^34,^ ^57,^ ^61,^ ^67,^ ^82^ | 1 publications ^63,^ ^66^ | 9 publications
| (10 comparisons) | (2 comparisons) | (12 comparisons)
Team/Staffing change | 25 publications ^6,^ ^10,^ ^12,^ ^13,^ ^15,^ ^16,^ ^19,^ ^23^ – ^25,^ ^28,^ ^30,^ ^32,^ ^34,^ ^35,^ ^38,^ ^40,^ ^41,^ ^45,^ ^46,^ ^48,^ ^49,^ ^53,^ ^57,^ ^62,^ ^67,^ ^72,^ ^73,^ ^75,^ ^77^ – ^79,^ ^82^ | 8 publications ^3,^ ^8,^ ^9,^ ^14,^ ^17,^ ^20,^ ^29,^ ^63,^ ^65,^ ^66^ | 33 publications
| (33 comparisons) | (10 comparisons) | (43 comparisons)
Telemedicine | 1 publications ^40^ | 1 publications ^65^ | 1 publications^‡^
| | (1 comparisons) | (1 comparisons)
Change in medical record system | 5 publications ^5,^ ^6,^ ^25,^ ^32,^ ^40,^ ^67^ | 2 publications ^2,^ ^54,^ ^65^ | 7 publications
| (6 comparisons) | (3 comparisons) | (9 comparisons)
Total | 48 | 15 publications | 63 publications
| (64 comparisons) | (18 comparisons) | (82 comparisons)

* Includes 6 publications (with 7 comparisons) that are quasi-RCTs ^3,^ ^8,^ ^9,^ ^17,^ ^43,^ ^58,^ ^64^ and 9 publications (with 11 comparisons that are controlled before-after ^2,^ ^4,^ ^14,^ ^20,^ ^21,^ ^29,^ ^36,^ ^54,^ ^63,^ ^65,^ ^66^

† CME refers to traditional CME in the form of educational workshops or meetings.

‡ The intervention group remained the same for both comparisons but the control group differed resulting in a difference in the study design; the first comparison for this study was a randomized control trial; the second comparison for this study had a controlled before-after design.

Table 3 Number of different quality improvement strategies included in articles

Number of QI types in intervention | Number of comparisons
| RCTs | Non-RCTs* | Total
Single QI type | 14 ^5,^ ^31^ – ^34,^ ^39,^ ^47,^ ^53,^ ^56,^ ^57,^ ^74,^ ^80^ – ^82^ | 3 ^4,^ ^36,^ ^64^ | 17
Multiple (total) | 50 | 15 | 65
2 QI strategies | 21 ^1,^ ^11,^ ^16,^ ^18,^ ^19,^ ^27,^ ^37,^ ^42,^ ^44,^ ^48^ – ^51,^ ^56,^ ^59,^ ^60,^ ^70,^ ^71,^ ^75,^ ^77^ – ^79^ | 6 ^8,^ ^20,^ ^43,^ ^58,^ ^63,^ ^66^ | 27
3 QI strategies | 15 ^7,^ ^10,^ ^12,^ ^15,^ ^22,^ ^26,^ ^40,^ ^41,^ ^45,^ ^46,^ ^52,^ ^68,^ ^69,^ ^72,^ ^76^ | 6 ^3,^ ^14,^ ^21,^ ^29,^ ^54,^ ^65^ | 21
4 QI strategies | 10 ^6,^ ^13,^ ^23,^ ^24,^ ^28,^ ^30,^ ^55,^ ^61,^ ^62,^ ^73^ | 3 ^2,^ ^9,^ ^17^ | 13
5 QI strategies | 3 ^35,^ ^38,^ ^67^ | 0 | 3
6 QI strategies | 1 ^25^ | 0 | 1

* Includes 6 publications (with 7 comparisons) that are quasi-RCTs ^3,^ ^8,^ ^9,^ ^17,^ ^43,^ ^58,^ ^64^ and 9 publications (with 11comparisons that are controlled before-after studies ^2,^ ^4,^ ^14,^ ^20,^ ^21,^ ^29,^ ^36,^ ^54,^ ^63,^ ^65,^ ^66^

Table 4 Quality improvement strategy combinations

IQ Strategy Combination* | Number of Comparisons | References
PtE, OC | 9 | ^1,^ ^16,^ ^19,^ ^48,^ ^49,^ ^75,^ ^77^ – ^79^
FR, Aud, PvE | 4 | ^3,^ ^26,^ ^68,^ ^69^
OC | 6 | ^32,^ ^34,^ ^36,^ ^53,^ ^57,^ ^82^
FR, PtR | 3 | ^37,^ ^70,^ ^71^
FR, PtE, SMx, OC | 4 | ^17,^ ^35,^ ^62,^ ^73^
PvE | 4 | ^4,^ ^31,^ ^47,^ ^74^
FR, PtE, OC | 3 | ^10,^ ^45,^ ^72^
PtE, SMx, PtR | 3 | ^7,^ ^52,^ ^76^
Aud, PvE | 2 | ^27,^ ^44^
PvE, PtE | 2 | ^63,^ ^66^
FR | 2 | ^58,^ ^64^
FR, PtR, OC | 2 | ^40,^ ^65^
FR, SMx | 2 | ^42,^ ^50^
FR, PtE, SMx, PtR | 2 | ^30,^ ^55^
PtR | 3 | ^56,^ ^80,^ ^81^
PvR | 2 | ^5,^ ^39^
PvR, PvE | 2 | ^18,^ ^51^
PtE, PtR, OC | 2 | ^14,^ ^29^
PtE, SMx, OC | 2 | ^15,^ ^41^
Aud | 1 | ^33^
Aud, FR | 1 | ^60^
Aud, PvE, PtR, OC | 1 | ^2^
Aud, PtR, OC | 1 | ^54^
PvE, PtE, OC | 1 | ^12^
PvE, PtE, SMx | 1 | ^21^
PvE, PtE, SMx, OC | 1 | ^24^
FR, PvE | 1 | ^43^
FR, PvE, PtE, OC | 1 | ^13^
FR, OC | 1 | ^8^
FR, PtE, PtR, OC | 1 | ^23^
FR, PtE, SMx | 1 | ^22^
OC, Fin | 1 | ^11^
PvR, FR, Aud, PvE, OC | 1 | ^67^
PvR, FR, Aud, PvE, PtE, OC | 1 | ^25^
PvR, FR, PtE, OC | 1 | ^9^
PvR, OC | 1 | ^20^
PvR, PtE, PtR, OC | 1 | ^6^
PvR, PtE, OC | 1 | ^46^
PtE, SMx | 1 | ^59^
PtE, SMx, PtR, OC | 1 | ^28^
PtE, SMx, PtR, OC,Fin | 1 | ^38^
PtE, SMx, OC, Fin | 1 | ^61^
| 82

* Aud—audit and feedback to provider; FR—facilitated relay of information to provider; Fin—financial incentives; OC—organizational change; PtE—patient education; PtR—patient reminder; PvE—provider education; PvR—provider reminder; SMx—resource for patient self-management.

Studies analyzed a mix of outcomes. Ten studies reported disease identification outcomes. Most studies reported clinical and process outcomes (Appendix G). Among studies reporting clinical outcomes, 60 comparisons had sufficient information to calculate quantitative results. Among the 40 comparisons reporting SBP as a measure of disease control, 33 (83 percent) reported sufficient information to perform a quantitative analysis. Among the 49 comparisons reporting DBP as a measure of disease control, 43 (88 percent) reported sufficient information to calculate quantitative results. Among the 23 comparisons reporting proportion of patients achieving SBP within a certain range, 14 (61 percent) reported sufficient information to calculate quantitative results. Among the 28 comparisons reporting proportion of patients achieving DBP within a certain range, 16 (57 percent) supplied sufficient information for quantitative analysis. Among the 19 comparisons reporting process outcomes involving provider adherence to recommended care, 10 (53 percent) supplied sufficient information for quantitative analysis. Among the 28 comparisons reporting outcomes involving patient adherence, only 5 (18 percent) supplied sufficient information for quantitative analysis.

## Analysis by Outcome Measures

### Effect of Quality Improvement Strategies on Disease Identification and Initial Followup Measures

A total of 10 studies assessed disease identification and/or initial followup appointments. ^106,^ ^109,^ ^110,^ ^124,^ ^138,^ ^141,^ ^151,^ ^158,^ ^165,^ ^166^ Many of these studies also assessed other outcomes, most commonly disease control. Table 5 summarizes the setting, interventions, and results of these studies. Studies of disease identification took place either in a medical setting, for example in a clinic, or in the community, for example at a work site, community center, or some other venue outside of the health care setting. The majority of these studies (6 of 10) were conducted at a clinic. Among the interventions in the clinic setting, the most common QI strategies were patient and/or provider reminders. Two studies reported a work site intervention, which included identification of hypertensives at the work site, and then a comparison of different followup treatment strategies. ^138,^ ^166^ The remaining studies of community-based screening often involved public education and appropriate followup of individuals identified as hypertensive.

Table 5 Screening studies

Author | Screening Intervention | Screening Setting | Results | Type of Screening Measure(s)
Aubin, 1994 ^2^ | “Operational incentives to increase hypertension screening”: | Clinic | [underlined: Control group]: | [underlined: Screening Rate:]
non-RCT (CBA) | Reference guide, placed in physician's offices | N = 13 providers, | Screening rates decreased from 71.9% to 59.8% | Percent of individuals who had blood pressure measured.
| Chart aids for the recording of BP measurements | 817 patients | [underlined: Intervention group]: | Control vs. Intervention:
| Follow up system and protocol | | Screening rates increased from 59.8% to 78.7% | P < 0.001 at baseline;
| Control group: Usual care | | Note: Control group had high screening rate to start with. Authors noted that there was a medical audit of practices in this group at baseline. | P < 0.001 at end of study
Barnett, 1983 ^5^ | Automated computer surveillance system used to monitor patient population with elevated diastolic BP and poor follow-up rates. Providers received automatic computer-generated reminders for all patients not adhering to standard follow-up procedures. | Clinic | 6–12 month follow-up period: | [underlined: Follow-up Rate] (attempted or accomplished):
RCT | Control group: Usual care | N = 115 patients | [underlined: Control group]: | Percent of patients with elevated blood pressure who had follow-up
| | | 25% follow-up rate; 31% had Repeat BP recorded | P < 0.01 (6–12 months)
| | | [underlined: Intervention group]: | P < 0.01 (6–24 months)
| | | 49% follow-up rate; 49% had Repeat BP recorded | [underlined: Repeat BP recorded]:
| | | 6–24 month follow-up period: | P < 0.05 (6–12 months)
| | | [underlined: Control group]: | P < 0.05 (6–24 months)
| | | 46% follow-up rate; 52% had Repeat BP recorded
| | | [underlined: Intervention group]:
| | | 98% follow-up rate;70% had Repeat BP recorded
Bass, 1986 ^6^ | Medical assistant administered hypertension screening, education, compliance, and follow-up activities in family practice setting. Medical charts were tagged to remind providers to measure patient's BP. A “tickler” file system tracked patients due for follow-up. Patient appointments were filed on an index card by month of visit; the card was removed from the file when the patient attended the appointment. Cards remaining at the end of the month received follow-up. | Clinic | [underlined: Control group]: | [underlined: Screening Rate:]
RCT | Patients received post card reminders to have BP checked. | N = 34 practices, | 80% screened at least once; 57% screened at least twice | Percent of patients who had blood pressure measured;
| Control group: Usual care | 32,124 patients | [underlined: Intervention group]: | [underlined: Followup Rate]:
| | | 90.8% screened at least once; 70.3% screened at least twice | Percent of patients with elevated blood pressure who had follow-up
| | | Note: Authors concluded that the higher rates of screening did not influence outcomes, probably because the family doctors were identifying higher risk groups regardless of screening practice. | Intervention versus control group patients were:
| | | | more likely to have lower SBP
| | | | (P < 0.02)
| | | | more likely to be more compliant
| | | | (P < 0.05)
| | | | more likely to be very satisfied with care (P < 0.01)
Foote, 1983 ^19^ | Worksite hypertension screening conducted at 4 sites. | Community (Work site) | Screening rates reported for Sites 1, 2, 3, and 4 (83%, 75%, 77%, 66%) | [underlined: Screening Rate:]
RCT | Site 1: Screening and referral to a physician only (Control) | N = 4 worksites, 11,196 patients | Percent of employees identified as hypertensive being treated before versus after study: | Percent of patients who had blood pressure measured;
| Site 2: Screening, referral to a physician, and semiannual follow-up visits | | Site 1: 49% to 84% | Percent of patient with hypertension who are treated (and identified as hypertensive)
| Site 3: Screening, referral to a physician, and more frequent follow-ups as needed | | Site 2: 49% to 96% | Site 1: Significant increase in proportion under treatment (P < 0.001), but not in proportion with adequate blood pressure control.
| Site 4: Screening and on-site treatment by a physician. | | Site 3: 33% to 96% | Sites 2, 3, and 4:
| | | Site 4: 40% to 98% | Significant increase in proportion under treatment (P < 0.001) and in proportion with adequate blood pressure control (P < 0.001).
| | | | No statistical comparison between control and intervention
Markov,1986 ^36^ | Work site hypertension screening. Active prevention group screened annually and referred to cardiovascular outpatient department for further testing and treatment. | Community (Work site) | [underlined: Control group]: | [underlined: Percent of Effectively Treated Patients]
non RCT (CBA) | Control group: Annual screenings; individuals with elevated blood pressure referred to routine care. | N = 5,563 patients | Effectively treated patients increased from 4% to 11.9% within 5 years. | (i.e., stable decrease in DBP below 90 mmHg, or DBP decrease by 10–15% from initial screening to final 5^th^ year of screening):
| | | [underlined: Intervention group]: | P < 0.01 for change in proportion of effectively treated patients in intervention group
| | | Effectively treated patients increased from 7.3% to 25.2% within 5 years. | P < 0.01 for change in proportion of effectively treated patients in control group
| | | | No statistical comparison between control and intervention
Robson, 1989 ^49^ | Health promotion nurse assisted physicians in recording BP during regular appointments. Computer system allocated patients into groups, depending on their risk score (based on BP measure). Nurse ran monthly computer searches and followed up with high risk patients and those without any record of risk factors. | Clinic | Percent patients with BP recorded within 5 years: | [underlined: Screening rate] (Percent of patients with BP checked initially)
RCT | Control group: General practitioners managed patients; recorded blood pressure and history of smoking in computerized record. | 3,117 patients | [underlined: Control group]: Increased from 62% to 73%. | Control versus intervention:
| | | [underlined: Intervention group]: Increased from 65% to 93%. | P < 0.001 for proportion of patients who had BP recorded within preceding 5 years.
| | | Percent hypertensives with BP recorded within 1 year at end of study: | [underlined: BP recorded at a follow-up time in patients identified as hypertensive]
| | | [underlined: Control group]: 69% | P < 0.001 for proportion of patients with HTN or who had fewer than 3 readings in the HTN range but had not had BP recorded within the preceding year.
| | | [underlined: Intervention group]: 97%
Fortmann, 1990 ^21^ | Annual cross-sectional surveys of randomly selected households, and 4 repeated surveys of a cohort. Mass media and education programs for public and health professionals in the study cities. | Community | For cohort study - | [underlined: Percent of hypertensives aware of HTN]
non RCT (CBA) | Control group: Usual care included 2 cities where no mass media education was provided. | N = 4 cities, 2,364 patients | Percent of hypertensives aware: | Control versus intervention:
| | | [underlined: Control]: 58.8% to 64.3% | P < 0.01 at baseline.
| | | [underlined: Intervention]: 42.2% to 55.9% | Results at end of study not significant.
| | | Percent of hypertensives under treatment: | [underlined: Percent of hypertensives under treatment]:
| | | [underlined: Control]: 41% to 44.9% | P < 0.05 at baseline.
| | | [underlined: Intervention]: 27.7% to 32.5% | Results at end of study not significant.
McDowell, 1989 ^39^ | Patients in 4 family practices received one of the following interventions aimed at encouraging patients to have their BP checked: | Clinic | Percent of individuals who had blood pressure measured: | [underlined: Screening rate] Percent of patients without BP checked in last year who have BP reading within the study year:
RCT | 1 Letter reminder; 2 Telephone reminder; 3 Physician reminder; 4 Randomized control group; 5 Two additional control practices did not participate in the trial and patients were not issued reminders | N = 4,247 families, 5,744 patients | [underlined: Control group]: 21.1% | P < 0.001 for difference between the 3 intervention groups and the control group.
| | | [underlined: Letter reminder]: 35.7% | P < 0.001 for differences among the 3 groups.
| | | [underlined: Telephone reminder]: 24.1% | P < 0.001 for difference between physician intervention and control.
| | | [underlined: Physician reminder]: 30.7%
| | | [underlined: Control Practices] (not randomized): 18.6%
Velez, 1985 ^56^ | Patient and providers were randomized to receive reminders: | Clinic | Percent of patients with elevated blood pressure who had follow-up: | [underlined: Percent of patients returning to physician after high blood pressure reading]:
RCT | 1 Patient Letter only; 2 Provider Letter only; 3 Both Patient and Provider Letter | N = 74 patients | [underlined: Control Group]: 29% | P = 0.012 for main effects of patient letter.
| Control Group: Patients informed of their elevated blood pressure and the need to follow-up with their local physician | | [underlined: Patient Letter]: 62% | P = 0.334 for main effects of physician letter
| | | [underlined: Provider Letter]: 39% | P = 0.72 for interaction effects of patient letter X physician letter
| | | [underlined: Both Letters]: 64%
| | | Note: 60% of patients were previously treated for HTN, and there were significant differences in this rate between intervention groups, but stratification did not change the results significantly.
Krishan, 1981 ^63^ | Public education via local radio and newspapers. Providers offered educational outreach program. | Community | 2 Control communities were compared with Intervention community: | [underlined: Percent of hypertensives on medications]:
non-RCT (CBA) | Community screening. Those identified with high blood pressure were offered a stepped care approach for the treatment of HTN in a special community hypertension clinic; patients could also follow-up with their own physicians. | N = 3 regions, 740 patients | The percentage of patients receiving hypertensive medications reported at baseline and 1^st^ year had no significant differences between communities in first two periods, but the intervention group had a higher rate in the final 5^th^ year (61.4% and 55.4% in control communities versus 68.4% in intervention community) | Insignificant difference at baseline and 1^st^ year
| Control group: Usual care | | Note: Only patients who participated in 5-year follow-up survey had data reported. | P = 0.01 for intervention community versus control communities at 5 years

Overall, in the studies of disease identification, outcomes measured were varied. Given the small number of studies and the heterogeneity of both the interventions and the outcomes, we were unable to perform meaningful analyses of pooled data, and therefore do not report summary data for screening studies. Most of the interventions led to some improvement in a screening related measure (Table 5).

Of the screening strategies evaluated, some strategies which demonstrated positive results included work site screening/followup, use of patient reminder letters, computer identification of patients with historically poor followup (combined with computer-generation of physician reminders), and the addition of a health promotion nurse to identify and followup with high-risk patients. One work site screening study involved 11,196 employees, and compared work site screening and referral of hypertensives to a physician (control group) with work site screening, referral, and more frequent followup or on-site treatment for hypertensives by a work site physician (three intervention groups). ^166^ The study reported higher rates of treatment at the end of the study in the intervention groups (96 percent or higher for intervention groups, compared with 84 percent for the control). Two studies found positive results with the use of patient letter reminders. ^141,^ ^158^ One of these studies involved 5744 patients and evaluated several interventions aimed at encouraging patients to have their BP checked, including letter reminders. ^141^ In this study, 35.7 percent of patients who received letter reminders subsequently had their blood pressure measured, compared with 21.1 percent of patients in the control group. ^141^ The other screening study evaluated patient reminder letters that encouraged patients with high blood pressure to receive followup, and found that 62 percent of the patients who received the reminder letter subsequently had followup, compared with 29 percent in the control group. ^158^ Another screening study evaluated the efficacy of an automated computer surveillance system to monitor patients with elevated BP and poor followup rates, and which generated reminders to providers for all patients not adhering to standard followup procedures. ^109^ This study involved 115 patients, and found, over a 6–24 month followup period, that 98 percent of the intervention group had followup over this period, and 70 percent had a repeat BP recorded, compared with a 46 percent followup rate in the control group, with a 52 percent repeat BP recorded rate. ^109^ One of the screening studies evaluated the efficacy of a health promotion nurse to identify and followup with high-risk patients (using a computer system to search for high-risk patients). ^151^ This study involved 3117 patients, and found that over the course of the five-year study, patients in the intervention group increased the frequency with which their BP was recorded from 65 percent to 93 percent. The control group had a smaller increase in the same measure, from 62 percent to 73 percent, over the course of the study.

### Effect of Quality Improvement Strategies on Measures of Disease Control

Effect of quality improvement strategies on mortality. Six studies reported mortality outcomes. ^20,^ ^105,^ ^110,^ ^118,^ ^131,^ ^165^ Two of these studies were large clinical trials, the Multiple Risk Factor Intervention Trial (MRFIT), and the Hypertension Detection and Follow-up Program (HDFP), a major clinical trial. ^20,^ ^105^ The MRFIT study was a primary prevention trial that tested the effect of a multifactor intervention program on coronary heart disease mortality in high-risk men aged 35–57 years. The “special intervention” (SI) included dietary advice for lowering blood cholesterol levels, counseling aimed at cessation for cigarette smokers, and “stepped care” treatment for hypertension for those with elevated BP. The SI was compared with usual care in the community. The trial included a planned initial followup in February, 1982; at that point, coronary heart disease and all-cause mortality rates were similar for SI and usual care. This finding was attributed, in part, to the substantially lower than expected death rate in the usual care group. After the initial results were reported in 1982, plans were made for additional analyses after ten-year followup of the participants. During ten-year followup, there were 317 deaths among 4019 SI participants (7.9 percent), and 353 deaths among 3993 usual care participants (8.8 percent). These rates were also reported as rates per 1000 person-years of 7.55 per 100 in the intervention group, and 8.48 per 1000 in the control group (P = 0.13). The data show a trend toward lower death rate in the SI group, but it was not statistically significant. It is not possible to distinguish the effect of the QI strategy components of the intervention from the effect of the specific drugs used, nor is it possible to distinguish the effects of blood-pressure-lowering from the effects of the cholesterol-lowering and smoking cessation components.

The HDFP examined a stepped care regimen in which participants were offered a free, standardized program of antihypertensive therapy in HDFP centers. Treatment approaches included the use of techniques believed to enhance patient adherence. Economic barriers to treatment were removed, to the extent possible, with provision of drugs, visits to the centers, laboratory tests, and transportation at no cost to the participant. Waiting times were minimized by use of additional allied health personnel, and appointments were available at convenient hours. Treatment included stepwise increases in medication to bring patients to or below their goal DBP. Patients were randomly assigned either to stepped care or usual care. Mortality from all causes was the primary endpoint of the study. During five-year followup, there were 349 deaths among 5485 stepped care participants (6.4 percent), and 419 deaths among 5455 usual care participants (7.9 percent). These rates were also reported as life table death rates per 100, of 6.4 per 100 in the intervention group, and 7.7 per 100 in the control group, representing a 16.9 percent relative risk reduction in mortality in the stepped care group (P < 0.01). The HDFP study also reported cardiovascular mortality as a secondary outcome: there were 195/5485 (3.6 percent) cardiovascular deaths in the stepped care group, and 240/5455 (4.4 percent) cardiovascular deaths in the control group (statistical comparison not reported). Because mortality was the primary endpoint of the study, and the difference in mortality was statistically significant, we can conclude that the stepped care approach, as implemented in the HDFP, was effective in lowering mortality risk. It is not possible to distinguish which component of stepped care, such as drug choice or QI strategies, was responsible for the benefit.

Another study reporting mortality rates used multiple QI strategies (provider reminders, patient education, patient reminders, and organizational change) in 34 family practices in Canada, involving 32,124 patients. ^110^ This study reported similar all-cause and cardiovascular mortality in control (1.6 percent, and 0.7 percent, respectively) and intervention (1.5 percent, and 0.7 percent, respectively) groups. This study did not include outcome measures for disease control in a format that was quantifiable for inclusion in our disease control analyses.

The fourth study reporting mortality outcomes, which also reported disease control outcomes included in our pooled analyses, was a study of a nurse practitioner intervention in three specialist hypertension clinics in Scotland, involving 396 patients. ^118^ The QI strategies included patient education, patient reminders, and organizational change. This study reported similar mortality rates in the control and intervention groups: 29/198 (15 percent) and 23/198 (12 percent) all-cause and cardiovascular mortality, respectively, in the control group, and 25/198 (13 percent) and 17/198 (9 percent) all-cause and cardiovascular mortality, respectively, in the intervention group.

A fifth study provided a special intervention for young, urban, African American men. ^131^ The study included an educational intervention for both control and intervention study arms, including explanation of BP, goal BP, importance of remaining in care and adhering to treatment, referral to a physician if necessary, answers to questions, and a wallet card on which to record BP. In addition, men in the special intervention group also received individualized counseling, monthly telephone calls, and a home visit. This study reported mortality outcomes as one of several reasons for nonattendance at followup visits: 1/101 in usual care group, and 5/103 in the special intervention group. Mortality outcomes were not a primary outcome measure in this small study.

The sixth study reporting mortality outcomes was the Mayo three-community hypertension control program, which included two comparisons. ^165,^ ^167^ This study focused on individuals with BP at or above SBP 160 mmHg or DBP 95 mmHg in three different communities. The intervention included a special community hypertension clinic. Death rates at five-year followup were reported as 12/153 (6.2 percent) and 5/249 (1.8 percent) in the two different control areas, and 15/237 (5.4 percent) in the intervention area. Mortality outcomes were not a primary outcome measure in this small study.

### Effect of Quality Improvement Strategies on Blood Pressure Control

A total of 33 comparisons assessed reduction in SBP, and 43 comparisons assessed reduction in DBP. The vast majority of studies showed improvements in these outcomes associated with the QI intervention (Appendix G). The median reduction in SBP was 4.5 mmHg (IQ range: 1.5, 11.0), and median reduction in DBP was 2.1 mmHg (IQ range: -0.2, 5.0) (Table 6a). Fourteen comparisons assessed the effect of the QI strategy on the proportion of patients with blood pressure in the target SBP range, and 16 comparisons assessed the effect of the QI strategy on the proportion of patients with blood pressure in the target DBP range (Appendix G and Table 6a). In these comparisons, the median increase in the proportion of patients in target SBP range and DBP range in these comparisons was 16.2 percent (IQ range: 10.3, 32.2), and 6.0 percent (IQ range: 1.5, 17.5), respectively. In these studies, QI strategies had a clinically meaningful effect on SBP, and on the proportion of patients achieving the target SBP range, and a more modest effect on DBP, and the proportion of patients achieving the target DBP range.

Table 6a Effect of quality improvement strategies on blood pressure outcomes*

Type of QI | Median reduction in SBP (mmHg) | Median reduction in DBP (mmHg) | Median increase in proportion of patients achieving SBP in a certain range | Median increase in proportion of patients achieving DBP in a certain range
| [inter-quartile range]^†^ | [inter-quartile range]^†^ | [inter-quartile range]^†^ | [inter-quartile range]^†^
| N = number of comparisons | N = number of comparisons | N = number of comparisons | N = number of comparisons
All comparisons | 4.5 | 2.1 | 16.2 | 6.0
| [1.5, 11.0] | [-0.2, 5.0] | [10.3, 32.2] | [1.5, 17.5]
| N = 3 ^31,^ ^4,^ ^9,^ ^10,^ ^13,^ ^14,^ ^17,^ ^18,^ ^21^ – ^24,^ ^27,^ ^28,^ ^30,^ ^38,^ ^40^ – ^43,^ ^45,^ ^51,^ ^53,^ ^55,^ ^57,^ ^60,^ ^62,^ ^64,^ ^65,^ ^68,^ ^73,^ ^74,^ ^82^ | N = 43 ^1,^ ^4,^ ^7,^ ^9^ – ^11,^ ^13,^ ^14,^ ^17,^ ^18,^ ^21^ – ^24,^ ^26^ – ^28,^ ^30,^ ^34,^ ^35,^ ^38,^ ^40^ – ^43,^ ^45,^ ^51^ – ^53,^ ^55,^ ^57,^ ^60^ – ^66,^ ^68,^ ^73,^ ^74,^ ^76,^ ^82^ | N = 14 ^4,^ ^8,^ ^12^ – ^14,^ ^16,^ ^19,^ ^21,^ ^25,^ ^45,^ ^53,^ ^67,^ ^72,^ ^78^ | N = 16 ^4,^ ^7,^ ^14,^ ^15,^ ^21,^ ^26,^ ^29,^ ^38,^ ^54,^ ^58,^ ^60,^ ^61,^ ^68,^ ^69,^ ^74,^ ^79^
Provider reminders | 6.8 | 2.1 | -3.6 | NA
| [3.0, 9.4] | [0.9, 6.6] | [-5.7, -1.4]
| N = 3 ^9,^ ^18,^ ^51^ | N = 3 ^9,^ ^18,^ ^51^ | N = 2 ^25,^ ^67^ | N = 0
Facilitated relay of clinical data | 4.5 | 1.1 | 15.3 | 2.0
| [2.2, 11.5] | [-1.0, 3.4] | [2.0, 28.4] | [1.6, 5.0]
| N = 19 ^9,^ ^10,^ ^13,^ ^17,^ ^22,^ ^23,^ ^30,^ ^40,^ ^42,^ ^43,^ ^45,^ ^55,^ ^60,^ ^62,^ ^64,^ ^65,^ ^68,^ ^73,^ ^74^ | N = 20 ^9,^ ^10,^ ^13,^ ^17,^ ^22,^ ^23,^ ^26,^ ^30,^ ^35,^ ^40,^ ^42,^ ^43,^ ^45,^ ^55,^ ^60,^ ^62,^ ^64,^ ^65,^ ^68,^ ^73,^ | N = 6 ^8,^ ^13,^ ^25,^ ^45,^ ^67,^ ^72^ | N = 5 ^26,^ ^58,^ ^60,^ ^68,^ ^69^
Audit and feedback | 1.3 | 0.6 | -3.6 | 1.8
| [0.5, 1.6] | [0.5, 1.0] | [-5.7, -1.4] | [0.1, 4.3]
| N = 4 ^27,^ ^60,^ ^68,^ ^74^ | N = 4 ^26,^ ^27,^ ^60,^ ^68^ | N = 2 ^25,^ ^67^ | N = 6 ^26,^ ^54,^ ^58,^ ^60,^ ^68,^ ^69^
Provider education | 2.7 | 0.7 | 10.9 | 3.5
| [1.1, 6.0] | [-0.3, 3.3] | [1.4, 13.1] | [1.7, 11.3]
| N = 10 ^4,^ ^13,^ ^18,^ ^21,^ ^24,^ ^27,^ ^43,^ ^51,^ ^68,^ ^74^ | N = 13 ^4,^ ^13,^ ^18,^ ^21,^ ^24,^ ^26,^ ^27,^ ^43,^ ^51,^ ^63,^ ^66,^ ^68,^ ^74^ | N = 6 ^4,^ ^12,^ ^13,^ ^21,^ ^25,^ ^67^ | N = 6 ^4,^ ^21,^ ^26,^ ^60,^ ^68,^ ^69^
Patient education | 8.1 | 3.3 | 19.2 | 15.2
| [3.3, 11.8] | [0.4, 5.0] | [10.3, 36.4] | [7.3, 21.8]
| N = 18 ^1,^ ^9,^ ^10,^ ^13,^ ^14,^ ^17,^ ^21^ – ^24,^ ^28,^ ^30,^ ^38,^ ^41,^ ^45,^ ^55,^ ^62,^ ^73^ | N = 25 ^1,^ ^7,^ ^9,^ ^10,^ ^13,^ ^14,^ ^17,^ ^21^ – ^24,^ ^28,^ ^30,^ ^35,^ ^38,^ ^41,^ ^45,^ ^52,^ ^55,^ ^61^ – ^63,^ ^66,^ ^73,^ ^76^ | N = 10 ^12^ – ^14,^ ^16,^ ^19,^ ^21,^ ^25,^ ^45,^ ^72,^ ^78^ | N = 8 ^7,^ ^14,^ ^15,^ ^21,^ ^29,^ ^38,^ ^61,^ ^79^
Promotion of self-management | 3.6 | 2.1 | 13.4 | 9.4
| [2.1, 9.5] | [0.4, 5.0] | | [1.1, 13.4]
| N = 12 ^17,^ ^21,^ ^22,^ ^24,^ ^28,^ ^30,^ ^38,^ ^41,^ ^42,^ ^55,^ ^62,^ ^73^ | N = 17 ^7,^ ^17,^ ^21,^ ^22,^ ^24,^ ^28,^ ^30,^ ^35,^ ^38,^ ^41,^ ^42,^ ^52,^ ^55,^ ^61,^ ^62,^ ^73,^ ^76^ | N = 1 ^21^ | N = 5 ^7,^ ^15,^ ^21,^ ^38,^ ^61^
Patient reminders | 2.8 | 0.5 | 7.0 | 9.4
| [-1.5, 5.1] | [-2.1, 3.4] | | [1.1, 19.0]
| N = 8 ^14,^ ^23,^ ^28,^ ^30,^ ^38,^ ^40,^ ^55,^ ^65^ | N = 12 ^7,^ ^14,^ ^23,^ ^28,^ ^30,^ ^35,^ ^38,^ ^40,^ ^52,^ ^55,^ ^65,^ ^76^ | N = 1 ^14^ | N = 5 ^7,^ ^14,^ ^29,^ ^38,^ ^54^
Organizational change | 10.1 | 4.4 | 21.8 | 17.0
| [3.9, 14.0] | [-0.5, 6.9] | [9.0, 33.8] | [4.2, 24.5]
| N = 19 ^1,^ ^9,^ ^10,^ ^13,^ ^14,^ ^17,^ ^23,^ ^24,^ ^28,^ ^38,^ ^40,^ ^41,^ ^45,^ ^53,^ ^57,^ ^62,^ ^65,^ ^73,^ ^82^ | N = 23 ^1,^ ^9^ – ^11,^ ^13,^ ^14,^ ^17,^ ^23,^ ^24,^ ^28,^ ^34,^ ^35,^ ^38,^ ^40,^ ^41,^ ^45,^ ^53,^ ^57,^ ^61,^ ^62,^ ^65,^ ^73,^ ^82^ | N = 12 ^8,^ ^12^ – ^14,^ ^16,^ ^19,^ ^25,^ ^45,^ ^53,^ ^67,^ ^72,^ ^78^ | N = 7 ^14,^ ^15,^ ^29,^ ^38,^ ^54,^ ^61,^ ^69^
Financial incentives | -13.3 | 0.0 | NA | 4.2
| | [-2.0, 2.5] | N = 0 | [-1.1, 9.4]
| N = 1 ^38^ | N = 3 ^11,^ ^38,^ ^61^ | | N = 2 ^38,^ ^61^

* For reference 25, nurses were given training about ageing, clinical aspects of hypertension, personal interviews, health behavior change models, process of negotiation, and ethical aspects of home visits.

† When N=2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

### Effect of Quality Improvement Strategies on Provider Adherence

A total of 10 comparisons reported quantitative results of provider adherence to recommended practices (Appendix G and Table 6b). Overall, the median increase in percentage of providers adhering to recommendations was 3.0 percent (IQ range: 1.0, 5.5).

Table 6b Effect of quality improvement strategies on summary adherence outcomes

Type of QI | Median improvement in proportion of provider adherence to recommended practice | Median improvement in proportion of patient adherence
| [inter-quartile range] ^†^ | [inter-quartile range] ^†^
| N = number of comparisons | N = number of comparisons
All comparisons | 3.0 | 2.8
| [1.0, 5.5] | [1.9, 3.0]
| N = 10 ^3,^ ^4,^ ^10,^ ^20,^ ^25,^ ^26,^ ^44,^ ^58,^ ^67,^ ^69^ | N = 5 ^4,^ ^8,^ ^22,^ ^45,^ ^69^
Provider reminders | -1.3 | NA
| [-2.0, 2.9] | N = 0
| N = 3 ^20,^ ^25,^ ^67^
Facilitated relay of clinical data | 2.0 | 2.4
| [-0.4, 3.7] | [0.8, 5.0]
| N = 7 ^3,^ ^10,^ ^25,^ ^26,^ ^58,^ ^67,^ ^69^ | N = 4 ^8,^ ^22,^ ^45,^ ^69^
Audit and feedback | 2.7 | -2.7
| [-0.4, 3.7]
| N = 7 ^3,^ ^25,^ ^26,^ ^44,^ ^58,^ ^67,^ ^69^ | N = 1 ^69^
Provider education | 3.3 | 0.2
| [0.7, 5.0] | [-2.7, 3.0]
| N = 7 ^3,^ ^4,^ ^25,^ ^26,^ ^44,^ ^67,^ ^69^ | N = 2 ^4,^ ^69^
Patient education | 0.4 | 2.4
| [-1.3, 2.0] | [1.9, 2.8]
| N = 2 ^10,^ ^25^ | N = 2 ^22,^ ^45^
Promotion of self-management | NA | 2.8
| N = 0
| | N = 1 ^22^
Patient reminder | NA | NA
| N = 0 | N = 0
Organizational change | 0.4 | 6.8
| [-1.6, 3.3] | [1.9, 11.6]
| N = 4 ^10,^ ^20,^ ^25,^ ^67^ | N = 2 ^8^ ^45^
Financial incentives | NA | NA
| N = 0 | N = 0

† When N=2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

### Effect of Quality Improvement Strategies on Patient Adherence

Four studies with five comparisons reported results for patient adherence to medications or followup appointments. Overall, there was a median increase in percent of patient adherence of 2.8 percent (IQ range: 1.9, 3.0) (Appendix G and Table 6b).

## Analysis by Type of Quality Improvement Strategy

Table 2a lists the number of studies examining each major type of quality improvement strategy. For certain QI strategies, there were a large number of important substrategies for which meaningful outcomes were reported (Table 2b). Many studies used more than one QI strategy. The numbers of studies using each different combination of QI strategies is shown in Table 4. Table 6a shows the median effects of QI strategies on blood pressure outcomes, and Table 6b shows the effects of individual quality improvement strategies on provider and patient adherence outcomes. Since not all comparisons listed in Tables 2a and 2b had sufficient data to report all outcomes, the total number of comparisons in the median effect tables may be smaller than the total number listed in Tables 2a and 2b. When describing the results of each QI strategy, we do not differentiate those that used that particular QI strategy alone, from those that used it in conjunction with other strategies. This is because single QI strategies were seldom used alone (Table 4), especially in studies with adequate data for reporting median effects (Tables 7a and 7b). Mann-Whitney tests of significance are noted when P-values were less than 0.05 for analyses comparing results from studies with a particular QI strategy to studies without that particular strategy. This test of significance must be interpreted tentatively, as we conducted multiple sub-group analyses. Tables 8a and 8b show the effects of several quality improvement substrategies on outcomes.

Table 7a Effect of number of quality improvement strategies on blood pressure outcomes

Number of QI strategies employed in intervention | Median reduction in SBP (mmHg) | Median reduction in DBP (mmHg) | Median increase in proportion of patients in target SBP range | Median increase in proportion of patients in target DBP range
| [inter-quartile range]* | [inter-quartile range]* | [inter-quartile range]* | [inter-quartile range]*
| N = Number of comparisons | N = Number of comparisons | N = Number of comparisons | N = Number of comparisons
Single QI strategy | 10.9 | 4.8 | 23.1 | 14.6
| [4.9, 17.6] | [2.5, 10.2] | [13.8, 32.4] | [5.0, 24.2]
| N = 6 ^4,^ ^53,^ ^57,^ ^64,^ ^74,^ ^82^ | N = 7 ^4,^ ^34,^ ^53,^ ^57,^ ^64,^ ^74,^ ^82^ | N = 2 ^4,^ ^53^ | N = 2 ^4,^ ^74^
Two QI strategies | 1.5 | 0.3 | 31.5 | 7.0
| [1.0, 4.7] | [-0.3, 2.1] | [23.4, 38.5] | [6.0, 12.0]
| N = 7 ^1,^ ^18,^ ^27,^ ^42,^ ^43,^ ^51,^ ^60^ | N = 10 ^1,^ ^11,^ ^18,^ ^27,^ ^42,^ ^43,^ ^51,^ ^60,^ ^63,^ ^66^ | N = 4 ^8,^ ^16,^ ^19,^ ^78^ | N = 3 ^58,^ ^60,^ ^79^
Three QI strategies | 3.8 | 0.7 | 13.4 | 2.0
| [2.0, 10.1] | [-1.0, 5.0] | [9.7, 31.6] | [1.1, 19.0]
| N = 9 ^10,^ ^14,^ ^21,^ ^22,^ ^40,^ ^41,^ ^45,^ ^65,^ ^68^ | N = 13 ^7,^ ^10,^ ^14,^ ^21,^ ^22,^ ^26,^ ^40,^ ^41,^ ^45,^ ^52,^ ^65,^ ^68,^ ^76^ | N = 5 ^12,^ ^14,^ ^21,^ ^45,^ ^72^ | N = 9 ^7,^ ^14,^ ^15,^ ^21,^ ^26,^ ^29,^ ^54,^ ^68,^ ^69^
Four QI strategies | 9.2 | 3.7 | 12.0 | -1.1
| [4.2, 13.4] | [1.1, 8.0]
| N = 10 ^9,^ ^13,^ ^17,^ ^23,^ ^24,^ ^28,^ ^30,^ ^55,^ ^62,^ ^73^ | N = 11 ^9,^ ^13,^ ^17,^ ^23,^ ^24,^ ^28,^ ^30,^ ^55,^ ^61,^ ^62,^ ^73^ | N = 1 ^13^ | N = 1 ^61^
Five QI strategies | -13.3 | -0.6 | -5.7 | 9.4
| | [-2.2, 1.1]
| N = 1 ^38^ | N = 2 ^35,^ ^38^ | N = 1 ^67^ | N = 1 ^38^
Six QI strategies | NA | NA | -1.4 | NA
| N = 0 | N = 0 | N = 1 ^25^ | N = 0
All comparisons | 4.5 | 2.1 | 16.2 | 6.0
| [1.5, 11.0] | [-0.2, 5.0] | [10.3, 32.2] | [1.5, 17.5]
| N = 33 ^1,^ ^4,^ ^9,^ ^10,^ ^13,^ ^14,^ ^17,^ ^18,^ ^21^ – ^24,^ ^27,^ ^28,^ ^30,^ ^38,^ ^40^ – ^43,^ ^45,^ ^51,^ ^53,^ ^55,^ ^57,^ ^60,^ ^62,^ ^64,^ ^65,^ ^68,^ ^73,^ ^74,^ ^82^ | N = 43 ^1,^ ^4,^ ^7,^ ^9^ – ^11,^ ^13,^ ^14,^ ^17,^ ^18,^ ^21^ – ^24,^ ^26^ – ^28,^ ^30,^ ^34,^ ^35,^ ^38,^ ^40^ – ^43,^ ^45,^ ^51^ – ^53,^ ^55,^ ^57,^ ^60^ – ^66,^ ^68,^ ^73,^ ^74,^ ^76,^ ^82^ | N = 14 ^4,^ ^8,^ ^2^ – ^14,^ ^16,^ ^19,^ ^21,^ ^25,^ ^45,^ ^53,^ ^67,^ ^72,^ ^78^ | N = 16 ^4,^ ^7,^ ^14,^ ^15,^ ^21,^ ^26,^ ^29,^ ^38,^ ^54,^ ^58,^ ^60,^ ^61,^ ^68,^ ^69,^ ^74,^ ^79^

* When N=2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

Table 7b Effect of number of quality improvement strategies on summary adherence outcomes

Number of QI strategies employed in intervention | Median improvement in proportion of provider adherence to recommended practice | Median improvement in proportion of patient adherence
| [inter-quartile range]* | [inter-quartile range]*
| N = Number of comparisons | N = Number of comparisons
Single QI strategy | 6.7 | 3.0
| N = 1 ^4^ | N = 1 ^4^
Two QI strategies | 2.7 | 11.6
| [1.6, 4.8] | N = 18
| N = 3 ^20,^ ^44,^ ^58^
Three QI strategies | 3.7 | 1.9
| [3.0, 4.5] | [-0.38, 2.35]
| N = 4 ^3,^ ^10,^ ^26,^ ^69^ | N = 3 ^22,^ ^45,^ ^69^
Four QI strategies | NA | NA
| N = 0 | N = 0
Five QI strategies | -2.6 | NA
| N = 1 ^67^ | N = 0
Six QI strategies | -1.3 | NA
| N = 1 ^25^ | N = 0
All comparisons | 3.0 | 2.8
| [1.0, 5.5] | [1.9, 3.0]
| N = 10 ^3,^ ^4,^ ^10,^ ^20,^ ^25,^ ^26,^ ^44,^ ^58,^ ^67,^ ^69^ | N = 5 ^4,^ ^8,^ ^22,^ ^45,^ ^69^

* When N = 2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

Table 8a Effect of specific quality improvement sub-strategies on blood pressure outcomes

Type of QI Sub-Strategy | Median reduction in SBP (mmHg) | Median reduction in DBP (mmHg) | Median increase in proportion of patients achieving SBP in a certain range | Median increase in proportion of patients achieving DBP in a certain range
| [inter-quartile range]* | [inter-quartile range]* | [inter-quartile range]* | [inter-quartile range]*
| N = number of comparisons | N = number of comparisons | N = number of comparisons | N = number of comparisons
Provider education | 2.7 | 0.7 | 10.9 | 3.5
| [1.1, 6.0] | [-0.3, 3.3] | [1.4, 13.1] | [1.7, 11.3]
| N = 10 ^4,^ ^13,^ ^18,^ ^21,^ ^24,^ ^27,^ ^43,^ ^51,^ ^68,^ ^74^ | N = 13 ^4,^ ^13,^ ^18,^ ^21,^ ^24,^ ^26,^ ^27,^ ^43,^ ^51,^ ^63,^ ^66,^ ^68,^ ^74^ | N = 5 ^4,^ ^12,^ ^13,^ ^21,^ ^25,^ ^67^ | N = 6 ^4,^ ^21,^ ^26,^ ^68,^ ^69,^ ^74^
CME^†^ | 2.9 | 0.0 | 12.7 | 2.0
| [1.4, 5.3] | [-1.0, 0.8] | [11.4, 14.7] | [1.6, 5.0]
| N = 8 ^10,^ ^13,^ ^21,^ ^27,^ ^43,^ ^64,^ ^68,^ ^74^ | N = 11 ^10,^ ^13,^ ^21,^ ^26,^ ^27,^ ^43,^ ^63,^ ^64,^ ^66,^ ^68,^ ^74^ | N = 4 ^8,^ ^12,^ ^13,^ ^21^ | N = 5 ^21,^ ^26,^ ^68,^ ^69,^ ^74^
Educational outreach | 3.8 | 2.2 | -1.4 | 1.6
| | [0.7, 3.8] | [-3.6, 6.0] | [0.6, 7.5]
| N = 1 ^21^ | N = 2 ^21,^ ^26^ | N = 3 ^21,^ ^25,^ ^67^ | N = 3 ^21,^ ^26,^ ^69^
Distribution of printed materials | 1.7 | 0.7 | 4.2 | 2.0
| [-0.2, 3.4] | [0.3, 1.6] | [-2.5, 10.6] | [1.6, 5.0]
| N = 6 ^18,^ ^21,^ ^27,^ ^51,^ ^68,^ ^74^ | N = 7 ^18,^ ^21,^ ^26,^ ^27,^ ^51,^ ^68,^ ^74^ | N = 4 ^12,^ ^21,^ ^25,^ ^67^ | N = 5 ^21,^ ^26,^ ^68,^ ^69,^ ^74^
Organizational change | 10.1 | 4.4 | 21.8 | 17.0
| [3.9, 14.0] | [-0.5, 6.9] | [9.0, 33.8] | [4.2, 24.5]
| N = 19 ^1,^ ^9,^ ^10,^ ^13,^ ^14,^ ^17,^ ^23,^ ^24,^ ^28,^ ^38,^ ^40,^ ^41,^ ^45,^ ^53,^ ^57,^ ^62,^ ^65,^ ^73,^ ^82^ | N = 23 ^1,^ ^9^ – ^11,^ ^13,^ ^14,^ ^17,^ ^23,^ ^24,^ ^28,^ ^34,^ ^35,^ ^38,^ ^40,^ ^41,^ ^45,^ ^53,^ ^57,^ ^61,^ ^62,^ ^65,^ ^73,^ ^82^ | N = 12 ^8,^ ^12^ – ^14,^ ^16,^ ^19,^ ^25,^ ^45,^ ^53,^ ^67,^ ^72,^ ^78^ | N = 7 ^14,^ ^15,^ ^29,^ ^38,^ ^54,^ ^61,^ ^69^
Disease/Case management | 14.1 | 5.0 | 4.2 | -1.1
| [11.6, 16.4] | [1.4, 10.2] | [-2.5, 10.3] | N = 1 ^61^
| N = 3 ^13,^ ^57,^ ^82^ | N = 7 ^13,^ ^34,^ ^57,^ ^61,^ ^63,^ ^66,^ ^82^ | N = 4 ^12,^ ^13,^ ^25,^ ^67^
Team/Staffing change | 10.1 | 3.7 | 21.8 | 19.0
| [3.9, 14.0] | [-0.8, 6.9] | [9.0, 33.8] | [17.0, 30.0]
| N = 19 ^9,^ ^10,^ ^13,^ ^14,^ ^17,^ ^23,^ ^24,^ ^28,^ ^30,^ ^38,^ ^40,^ ^41,^ ^45,^ ^53,^ ^57,^ ^62,^ ^65,^ ^73,^ ^82^ | N = 23 ^9,^ ^10,^ ^13,^ ^14,^ ^17,^ ^23,^ ^24,^ ^28,^ ^30,^ ^34,^ ^35,^ ^38,^ ^40,^ ^41,^ ^45,^ ^53,^ ^57,^ ^62,^ ^63,^ ^65,^ ^66,^ ^73,^ ^82^ | N = 11 ^8,^ ^12^ – ^14,^ ^16,^ ^19,^ ^25,^ ^45,^ ^53,^ ^67,^ ^72,^ ^78^ | N = 5 ^14,^ ^15,^ ^29,^ ^38,^ ^79^
Telemedicine | 3.4 | -2.0 | NA | NA
| [2.3, 4.5] | [-1.6, -2.4] | N = 0 | N = 0
| N = 2 ^40,^ ^65^ | N = 2 ^40,^ ^65^
Change in medical record system | 3.4 | -2.0 | -3.6 | -2.0
| [2.3, 4.5] | [-1.6, -2.4] | [-5.7, -1.4] | N = 1 ^54^
| N = 2 ^40,^ ^65^ | N = 2 ^40,^ ^65^ | N = 2 ^25,^ ^67^

* When N = 2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

† CME refers to traditional CME in the form of educational workshops or meetings.

Table 8b Effect of specific quality improvement sub-strategies on summary adherence outcomes

Type of QI Sub-Strategy | Median improvement in proportion of provider adherence to recommended practice | Median improvement in proportion of patient adherence
| [inter-quartile range]* | [inter-quartile range]*
| N = number of comparisons | N = number of comparisons
Provider education | 3.3 | 0.2
| [0.7, 5.0] | [-2.7, 3.0]
| N = 7 ^3,^ ^4,^ ^25,^ ^26,^ ^44,^ ^67,^ ^69^ | N = 2 ^4,^ ^69^
CME^†^ | 3.3 | 4.5
| [2.7, 4.0] | [-2.7, 11.6]
| N = 5 ^3,^ ^10,^ ^26,^ ^44,^ ^69^ | N = 2 ^8,^ ^69^
Educational outreach | 3.0 | -2.66
| [-0.3, 3.8] | N = 1 ^69^
| N = 6 ^3,^ ^25,^ ^26,^ ^44,^ ^67,^ ^69^
Distribution of printed materials | 3.0 | -2.66
| [-0.3, 3.8] | N = 1 ^69^
| N = 6 ^3,^ ^25,^ ^26,^ ^44,^ ^67,^ ^69^
Organizational change | 0.4 | 6.8
| [-1.6, 3.3] | [1.9, 11.6]
| N = 3 ^10,^ ^20,^ ^25,^ ^67^ | N = 2 ^8,^ ^45^
Disease/Case management | -2.0 | NA
| [-2.6, -1.3] | N = 0
| N = 2 ^25,^ ^67^
Team/Staffing change | 2.0 | 6.8
| [-1.3, 3.3] | [1.9, 11.6]
| N = 5 ^3,^ ^10,^ ^20,^ ^25,^ ^67^ | N = 2 ^8,^ ^45^
Telemedicine | NA | NA
| N = 0 | N = 0
Change in medical record system | -2.0 | NA
| [-2.6, -1.3] | N = 0
| N = 2 ^25,^ ^67^

* When N = 2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

† CME refers to traditional CME in the form of educational workshops or meetings.

### Provider Reminders

Nine studies, including a total of 10 comparisons, used provider reminders alone (two comparisons), or in combination with other QI strategies (Table 2a and Table 4). Studies that used provider reminders, alone or in combination with other QI strategies, found a median reduction in SBP of 6.8. mmHg (IQ range: 3.0, 9.4) and a median reduction in DBP of 2.1 mmHg (IQ range: 0.9, 6.6). There were two comparisons using provider reminders as a QI strategy that reported outcomes for SBP in target range; both comparisons were from the same study, and reported a decrease in this outcome of 3.6 percent (IQ range: -5.7,-1.4) in the intervention group compared with the control group. ^128^ This study included three study arms: academic detailing, academic detailing plus Continuous Quality Improvement (CQI) teams, and usual care. Patients whose mean BP measurements over six months were less than 160/90 mmHg were classified as controlled. In this study, all study groups showed improvements in percent of patients with BP in target range. The usual care control group had a greater improvement than the provider reminder (e.g., academic detailing) groups, producing the decrease in median effect size. The authors commented that either contamination or a Hawthorne effect may have contributed to their generally negative findings, by moving usual care behavior in the direction hypothesized by the interventions.

Three comparisons utilizing provider reminders reported outcomes for provider adherence to hypertension treatment recommendations, and had mixed results, with a median effect of 1.3 percent decrease (Table 6b). Two of these comparisons were in the same study described in the preceding paragraph. ^128,^ ^168^ The third study ^123^ used a clinical pharmacist program that included provider reminders as part of the QI strategy; this study found an improvement in provider adherence to recommended management. No studies using provider reminders reported effects on patient adherence outcomes.

### Facilitated Relay of Clinical Data

Facilitated relay of clinical data was assessed as all (two comparisons), or part of the QI strategy in 23 studies, including a total of 31 comparisons (Table 2a and Table 4). Studies that used facilitated relay found a median reduction in SBP of 4.5 mmHg (IQ range: 2.2, 11.5), and a median increase in the percentage of patients with SBP in the target range of 15.3 percent (IQ range: 2.0, 28.4). The median effect for DBP was a reduction of 1 mmHg (IQ range: -1.0, 3.4) (Table 6a). There was a median increase in provider adherence of 2 percent (IQ range: -0.4, 3.7, seven comparisons), and a median increase in patient adherence of 2.4 percent (IQ range: 0.8, 5.0, four comparisons) (Table 6b).

### Audit and Feedback

Ten studies (with 13 comparisons) included audit and feedback alone (one comparison), or in combination with other QI strategies (Table 2a and Table 4). In these studies, there were small improvements in median SBP of 1.3 mmHg ( IQ range: 0.5, 1.6), median DBP of 0.6 mmHg ( IQ range: 0.5, 1.0), percentage of patients with DBP under control (1.8 percent, IQ range: 0.1, 4.3) (Table 6a), and median improvement in provider adherence to recommended practice of 2.7 percent ( IQ range: -0.4, 3.7) (Table 6b). There was a median reduction of 3.6 percent (IQ range: -5.7, -1.4) in patients in SBP target range. For SBP and proportion of patients in DBP range outcomes, studies with audit and feedback, alone or in combination, showed less of an improvement than studies without an audit and feedback component (P = 0.039 for SBP, and P = 0.036 for DBP range). Seven studies reported provider adherence outcomes with median improvement of 2.7 percent (IQ range: -0.4, 3.7) (Table 6b). Only one study reported an effect on patient adherence, and this was a net decrease of 2.7 percent (Table 6b). ^129^ This study used a multifaceted intervention with a goal of improving physician adherence by tailoring CME to deficiencies in physician performance identified by medical record review and a patient survey. The study included eight secondary hypotheses, of which one was that patients of physicians receiving the intervention were expected to show greater adherence to medication regimens.

### Provider Education

A total of 18 studies (including 22 comparisons) utilized provider education as all (four comparisons), or part of the QI strategy (Table 2a and Table 4). Among our included studies, the most frequently used provider education strategies were educational workshops, meetings (e.g., traditional CME), and/or lectures (live or computer-based), (19 of 22; 86 percent), and distribution of educational materials (16 of 22; 73 percent). In studies examining provider education, alone or in combination with other QI strategies, there was a median reduction in SBP of 2.7 mmHg (IQ range: 1.1, 6.0). There was a median increase of 10.9 percent (IQ range: 1.4, 13.1) in proportion of patients achieving SBP in the target range (Table 6a). In these studies, the median reduction of DBP was 0.7 mmHg (IQ range: -0.3, 3.3), and median increase in percentage of patients achieving DBP in the target range was 3.5 percent (IQ range: 1.7, 11.3) (Table 6a). For SBP and proportion of patients in SBP range outcomes, studies with provider education, alone or in combination with other QI strategies, showed less of an improvement than studies without a provider education component (P = 0.037 for SBP and P = 0.012 for SBP range). Median improvement in provider adherence with hypertension treatment recommendations was 3.3 percent (IQ range: 0.7, 5.0) in these studies (Table 6b). Two studies reported the effect of QI strategies that included provider education on patient adherence: one reported a decrease in patient adherence of 2.7 percent, and the other an increase of 3.0 percent (Table 6b, Appendix G).

### Substrategies of Provider Education

Because provider education includes so many types of QI strategies, we performed analyses of some educational substrategies, including CME, educational outreach, and distribution of printed materials (see Tables 8a and 8b). Most studies with provider education included CME, and therefore showed similar median effects in blood pressure outcomes as above. Studies involving CME as part of the quality improvement strategy also demonstrated similar improvements in provider adherence to recommended practices, and in patient adherence to medical regimen (see Table 8b). The few studies that included the substrategy of educational outreach generally showed improvements for these outcomes, but of lesser magnitude (see Tables 8a and 8b). Studies that used distribution of printed materials as part of the QI strategy showed a 1.7 mmHg improvement (IQ range: -0.2, 3.4) for SBP, and a 4.2 percent (IQ range: -2.5, 10.6) increase in the proportion of patients achieving SBP in the target range. However, the latter was based on only four studies (Table 8a). Results for DBP improvements were lesser in magnitude.

### Patient Education

A total of 33 studies (including 41 comparisons) included patient education as part of the QI strategy (see Table 2a). Patient education was utilized more than any other QI strategy. As described above, we included only studies that used patient education in conjunction with at least one other QI strategy. Studies that included patient education as part of the QI intervention had a median improvement of 8.1 mmHg for SBP (IQ range: 3.3, 11.8) and 3.3 mmHg for DBP (IQ range: 0.4, 5.0). These studies also reported improvement in percentage of patients achieving both SBP and DBP in the target ranges (19.2 percent, QI range: 10.3, 36.4; and 15.2 percent, IQ range: 7.3, 21.8 respectively) (see Table 6a, Appendix G). Only two studies that included patient education resulted in an increase in patient adherence of 1.9 percent and 2.8 percent (see Table 6b, Appendix G). Only two studies with patient education QI strategies reported provider adherence outcomes; one showed a decrease of 1.3 percent and the other an increase of 2.0 percent in provider adherence outcomes (see Table 6b, Appendix G). ^114,^ ^128^

### Promotion of Self-management

A total of 18 studies (including 20 comparisons) (see Table 2a) included patient self-management as part of the QI strategy. As with patient education, this strategy was only included if used in conjunction with other strategies. Studies that used patient self-management, in combination with other strategies, showed a median improvement in SBP of 3.6 mmHg (IQ range: 2.1, 9.5) and a median improvement in DBP of 2.1 mmHg (IQ range: 0.4, 5.0), and an increase in percentage of patients with either SBP in the target range (13.4 percent, one study) or DBP in the target range ( median improvement 9.4 percent; IQ range: 1.1, 13.4; five studies) (see Table 6a, Appendix G). Only one study assessed the effect of promotion of self-management on patient adherence, and this showed a positive effect (see Table 6b, Appendix G).

### Patient Reminders

A total of 16 studies (including a total of 22 comparisons) included patient reminders as a component of the QI strategy, or alone (three comparisons). Studies that used patient reminders, alone or in combination, showed a median reduction in SBP of 2.8 mmHg (IQ range: -1.5, 5.1), virtually no reduction in DBP (median effect 0.5 mmHg; IQ range: -2.1, 3.4), and increases in the overall percentages of patients with SBP and DBP in the target ranges (7.0 percent and 9.4 percent, IQ range: 1.1, 19.0, respectively). However, only one study reported SBP target range results (see Table 6a). No studies using patient reminders reported provider or patient adherence outcomes.

### Organizational Change

Organizational change was assessed in 36 studies (including a total of 45 comparisons), either alone (six comparisons), or in combination with other strategies. The most common types of organizational changes implemented were team staffing changes (e.g., addition of a new member to the health care team or a change in existing roles). Overall, studies including organizational change as part or all of the QI strategy demonstrated median improvement in SBP of 10.1 mmHg (IQ range: 3.9, 14.0), compared with a 2.3 mmHg median improvement for studies without an organizational change component (P = 0.007). Given the multiple comparisons for the Mann-Whitney significance test, even this low P-value may still be borderline. Studies including organizational change also showed median improvement in DBP of 4.4 mmHg (IQ range: -0.50, 6.9), at a potentially significant level, compared with studies that did not have an organizational change component (median improvement in DBP of 1.1 mmHg for studies without organizational change component; P = 0.04 for comparisons with, versus without, organizational change) (see Table 6a). The percentage of patients with SBP in the target range had a median improvement of 21.8 percent (IQ range: 9.0, 33.8), and DBP in the target range had a median improvement of 17.0 percent (IQ range: 4.2, 24.5) (see Table 6a). Studies utilizing organizational change had a median improvement in patient adherence by 6.8 percent (IQ range: 1.9, 11.6), but provider adherence appeared unaffected (median effect 0.4 percent; IQ range: -1.6, 3.3) (see Table 6b).

### Substrategies of Organizational Change

Because organizational change included several types of QI substrategies, we performed additional analyses for some of the commonly used substrategies. These included disease/case management, team staffing changes, use of telemedicine, and changes to medical record systems. Studies that included disease management/case management showed a median reduction of SBP of 14.1 mmHg (IQ range: 11.6, 16.4) and a median increase in the proportion of patients who achieved SBP in the target range of 4.2 percent (IQ range: -2.5, 10.3) (see Table 8a). Studies including the substrategy of team staffing change showed increases in the proportion of patients achieving SBP and DBP in target ranges of 21.8 percent (IQ range: 9.0, 33.8), and 19 percent (IQ range: 17.0, 30.0), respectively (see Table 8a). Studies including team staffing changes also showed a median increase in patient adherence of 6.8 percent (IQ range: 1.9, 11.6) (see Table 8b). Studies including telemedicine and changes to medical record systems had less of an effect. In these studies, none of the substrategies appeared to demonstrate an effect on provider adherence.

### Financial Incentives

Only three studies (including a total of three comparisons) included financial incentives as part of the QI strategy. Quantitative analysis was limited due to the small number of studies. One study reported a better improvement in the control group, which had a reduction of 13 mmHg SBP, relative to the intervention group. In this study, the control group had a higher mean BP at baseline, and achieved a post-intervention BP similar to that achieved by the intervention group, for an overall greater decrease in SBP in the control group. Three studies assessed the impact of financial incentives on DBP reduction: the median effect was 0.0. Two studies assessed the impact of financial incentives on the proportion of patients achieving SBP in a certain range, and showed an improvement in one study but not the other (see Table 6a and 6b). No studies using financial incentives reported outcomes for DBP range, provider or patient adherence.

## Other Analyses

### Clinical Information Systems

Nineteen studies (reporting 25 comparisons) used information systems in some aspect of the quality improvement strategy. Eight studies (reporting 12 comparisons) used them to identify eligible participants for study enrollment, eight (reporting 12 comparisons) included a clinical reminder based on an existing information system, two (reporting two comparisons) included a clinical decision support system, four (reporting five comparisons) included the collection of audit data based on an information system, and 14 (reporting 16 comparisons) included some other aspect of an information system. Tables 9a and 9b show the effect sizes of blood pressure and adherence outcomes for studies that included various uses of information systems, and reported quantitative results adequately for calculating median effects. Studies that included use of a clinical information system had a median effect on SBP reduction of 2.2 mmHg (IQ range: 1.1, 4.2), and on DBP reduction of 0.6 mmHg (IQ range: -1.3, 2.1). The median effect on proportion of patients in SBP target range was a decrease of 1.4 percent (IQ range: -3.6, 5.3), and in DBP target range was an increase of 1.8 percent (IQ: 0.1, 4.3). These effects were generally less than the effects seen in studies without information systems, particularly for the SBP in range outcome (Mann Whitney P = 0.03). There was a median effect increase of 2.7 percent (IQ range: -0.4, 5.0) in the proportion of providers adherent to recommended practice with the use of clinical information systems, and no apparent effect on the proportion of patients adherent to recommendations.

Table 9a Effect of information systems on blood pressure outcomes*

Type of Information System | Median reduction in SBP (mmHg) | Median reduction in DBP (mmHg) | Median increase in proportion of patients achieving SBP in a certain range | Median increase in proportion of patients achieving DBP in a certain range
| [inter-quartile range] ^†^ | [inter-quartile range] ^†^ | [inter-quartile range] ^†^ | [inter-quartile range] ^†^
| N = number of comparisons | N = number of comparisons | N = number of comparisons | N = number of comparisons
All information systems | 2.2 | 0.6 | -1.4 | 1.8
| [1.1, 4.2] | [-1.3, 2.1] | [-3.6, 5.3] | [0.1, 4.3]
| N = 10 ^13,^ ^22,^ ^24,^ ^27,^ ^40,^ ^43,^ ^60,^ ^62,^ ^65,^ ^68^ | N = 11 ^13,^ ^22,^ ^24,^ ^26,^ ^27,^ ^40,^ ^43,^ ^60,^ ^62,^ ^65,^ ^68^ | N = 3 ^13,^ ^25,^ ^67^ | N = 6 ^26,^ ^54,^ ^58,^ ^60,^ ^68,^ ^69^
Identification of eligible participants using information systems | 1.2 | 0.6 | NA | 2.0
| [1.0, 1.6] | [0, 0.7] | N=0 | [1.6, 5.0]
| N = 4 ^27,^ ^43,^ ^60,^ ^68^ | N = 5 ^26,^ ^27,^ ^43,^ ^60,^ ^68^ | | N = 5 ^26,^ ^58,^ ^60,^ ^68,^ ^69^
Reminders generated by existing clinical information system | 2.3 | -1.6 | -3.6 | 6.0
| [1.7, 3.4] | [-2.0, 0.2] | [-5.7, -1.4] | [5.0, 7.0]
| N = 3 ^40,^ ^60,^ ^65^ | N = 3 ^40,^ ^60,^ ^65^ | N = 2 ^25,^ ^67^ | N = 2 ^58,^ ^60^
Decision Support System | 1.2 | -0.7 | NA | NA
| [1.0, 1.5] | [-2.0, 0.6] | N = 0 | N = 0
| N = 2 ^27,^ ^43^ | N = 2 ^27,^ ^43^
Audit data gathered from clinical information systems | 1.5 | 1.0 | NA | 3.5
| [1.3, 1.8] | [0.5, 1.5] | N = 0 | [1.0, 5.5]
| N = 2 ^60,^ ^68^ | N = 2 ^60,^ ^68^ | | N = 4 ^54,^ ^58,^ ^60,^ ^68^

* Some subcategories of information systems strategies are not included in this table.

† When N=2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

Table 9b Effect of information systems on summary adherence outcomes*

Type of Information System | Median improvement in proportion of provider adherence to recommended practice | Median improvement in proportion of patient adherence
| [inter-quartile range] | [inter-quartile range]
| N = number of comparisons | N = number of comparisons
All Information Systems | 2.7 | 0.07
| [-0.4, 5.0] | [-2.66, 2.8]
| N = 7 ^20,^ ^25,^ ^26,^ ^44,^ ^58,^ ^67,^ ^69^ | N = 2 ^22,^ ^69^
Identification of eligible participants using information systems | 4.0 | -2.66
| [2.3, 5.0]
| N = 3 ^26,^ ^58,^ ^69^ | N = 1 ^69^
Reminders generated by existing clinical information system | -1.3 | NA
| [-2.0, -0.4] | N = 0
| N = 3 ^25,^ ^58,^ ^67^
DSS | NA | NA
| N = 0 | N = 0
Audit data gathered from clinical information systems | 1.7 | NA
| [0.6, 2.7] | N = 0
| N = 2 ^44,^ ^58^

* Some subcategories of information systems strategies are not included in this table.

† When N = 2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

In a number of studies (see Table 9a and 9b), information systems were used only to identify eligible participants for the study, and may even have been used for both intervention and control groups. When information systems were used this way, they may have contributed to the feasibility of the study by facilitating the identification of potential participants, but would not have been expected to contribute to improvements in outcome.

A small numbers of studies reported outcomes for use of information systems to generate reminders either to patients or to providers, and results were mixed. Two comparisons (from a single study) using a clinical decision support system reported SBP and DBP outcomes, with reductions in SBP of 1.0 mmHg in one comparison, and 1.5 mmHg in the other, but an increase in DBP of 2.0 mmHg in the first, and a reduction of 0.6 mmHg in the second comparison (Table 9a). One study, including two comparisons reporting SBP and DBP outcomes used an information system to generate audit data. These comparisons also showed mixed results. Three studies with four comparisons reported the increase in proportion of patients achieving DBP in target range; the median effect was an increase of 3.5 percent (IQ range: 1.0, 5.5).

The small number of studies using information systems, and the variability in their roles with respect to QI strategies, limit the conclusions that can be drawn about this particular intervention.

### Analysis of Number of Quality Improvement Strategies on Outcomes

The majority of studies employed a combination of QI strategies, rather than a single intervention (see Tables 3 and 4). The effect on blood pressure and adherence outcomes as a function of the number of QI strategies employed is shown in Tables 7a and 7b. For both SBP and DBP reductions, there was no clear pattern of increasing or decreasing effect as the number of QI strategies increased. For the SBP outcomes, the Mann-Whitney analysis comparing single QI strategies to multifaceted QI strategies (i.e., two or more QI strategies) had a P-value of 0.029 favoring single QI strategies, which has borderline significance given multiple comparisons. The results are likely confounded because the studies in the single QI strategy group use primarily organizational change strategy (i.e., three of five studies for SBP outcomes, and four of six studies for DBP outcomes). When assessing the percentage of patients with SBP in the target range, the largest increase was reported in studies employing two QI strategies, but this pattern was not present for DBP (Table 7a). There is no clear pattern of effect of number of QI strategies on adherence outcomes in our analysis, but again, there are few studies included in this analysis.

## Effect of Methodologic Features

We critically reviewed studies to discern major features in study design or analysis that were likely to affect their results. The methodologic features that we considered were random allocation of subjects to the intervention, blinding of providers to the treatment status, blinding of patients to the treatment status, unit of analysis the same as unit of allocation, and concealment of the allocation. These desirable study design features, when present, improve the likelihood that the effects observed in the study represent true effects. We assessed the relationship between these methodologic features and outcomes, including reported decreases in blood pressure (systolic and diastolic), increased percentage of patients with blood pressure in target ranges, percentage of providers adhering to recommended practices, and patient adherence to recommended practices.

### Effect of Methodologic Features on Blood Pressure Outcomes

As previously noted, 33 comparisons assessed reduction in SBP, and 43 comparisons assessed reduction in DBP. The majority of these were randomized controlled trials (25 of 33 (76 percent) of the comparisons assessing SBP; 33 of 43 (77 percent) of the comparisons assessing DBP (see Table 10a). Neither patients nor providers were blinded in the majority of studies. Unit of analysis was the same as the unit of allocation in two-thirds of the comparisons reporting SBP and DBP. However, in comparisons reporting target range outcomes, there were proportionally less studies with this design feature: only 29 percent of the SBP in target range comparisons, and 56 percent of the DBP in target range comparisons (see Table 10b). Concealment of allocation occurred in the minority of studies with SBP and DBP outcomes, but in the majority of studies with target range outcomes. With the exception of concealment of allocation, studies having positive design features had better median reduction in SBP; however, the inter-quartile ranges had substantial overlap, and Mann-Whitney tests did not show any significant differences by design feature. For other blood pressure outcomes, the comparative results by design feature were more mixed (e.g., RCT comparisons had lower values than non-RCTs for DBP and DBP in target range outcomes, while RCTs examining SBP in target range outcomes had higher values for this outcome than non-RCTs ), with no design feature analysis showing significance.

Table 10a Association of methodologic features* with decreased blood pressures

| Median reduction in SBP (mmHg) | | Median reduction in DBP (mmHg)
| [inter-quartile range] ^†^ | | [inter-quartile range] ^†^
| N = Number of comparisons | | N = Number of comparisons
| Design feature present | Design feature absent | Design feature present | Design feature absent
RCT | 6.8 | 4. 3 | 2.0 | 2.7
| [1.5, 13.0] | [3.1, 8.1] | [0.0, 5.0] | [-0.9, 4.6]
| N = 25 ^1,^ ^10,^ ^13,^ ^18,^ ^22^ – ^24,^ ^27,^ ^28,^ ^30,^ ^38,^ ^40^ – ^42,^ ^45,^ ^51,^ ^53,^ ^55,^ ^57,^ ^60,^ ^62,^ ^68,^ ^73,^ ^74,^ ^82^ | N = 8 ^4,^ ^9,^ ^14,^ ^17,^ ^21,^ ^43,^ ^64,^ ^65^ | N = 33 ^1,^ ^7,^ ^10,^ ^11,^ ^13,^ ^18,^ ^22^ – ^24,^ ^26^ – ^28,^ ^30,^ ^34,^ ^35,^ ^38,^ ^40^ – ^42,^ ^45,^ ^51^ – ^53,^ ^55,^ ^57,^ ^60^ – ^62,^ ^68,^ ^73,^ ^74,^ ^76,^ ^82^ | N = 10 ^4,^ ^9,^ ^14,^ ^17,^ ^21,^ ^43,^ ^63^ – ^66^
Providers blinded | 5.1 | 4.5 | 2.9 | 2.0
| [3.3, 6.8] | [1.3, 11.5] | [2.1, 3.7] | [-0.3, 5.0]
| N = 2 ^24,^ ^51^ | N = 31 ^1,^ ^4,^ ^9,^ ^10,^ ^13,^ ^14,^ ^17,^ ^18,^ ^21^ – ^23,^ ^27,^ ^28,^ ^30,^ ^38,^ ^40^ – ^43,^ ^45,^ ^53,^ ^55,^ ^57,^ ^60,^ ^62,^ ^64,^ ^65,^ ^68,^ ^73,^ ^74,^ ^82^ | N = 2 ^24,^ ^51^ | N = 41 ^1,^ ^4,^ ^7,^ ^9^ – ^11,^ ^13,^ ^14,^ ^17,^ ^18,^ ^21^ – ^23,^ ^27,^ ^28,^ ^30,^ ^34,^ ^35,^ ^38,^ ^40^ – ^43,^ ^45,^ ^52,^ ^53,^ ^55,^ ^57,^ ^60^ – ^66,^ ^68,^ ^73,^ ^74,^ ^76,^ ^82^
Patients blinded | 6.8 | 4.3 | 1.5 | 2.1
| [1.5, 7.3] | [1.7, 12.5] | [0.7, 2.8] | [-0.8, 5.0]
| N = 7 ^4,^ ^9,^ ^30,^ ^51,^ ^60,^ ^68,^ ^74^ | N = 26 ^1,^ ^10,^ ^13,^ ^14,^ ^17,^ ^18,^ ^21^ – ^24,^ ^27,^ ^28,^ ^38,^ ^40^ – ^43,^ ^45,^ ^53,^ ^55,^ ^57,^ ^62,^ ^64,^ ^65,^ ^73,^ ^82^ | N = 8 ^4,^ ^9,^ ^26,^ ^30,^ ^51,^ ^60,^ ^68,^ ^74^ | N = 35 ^1,^ ^7,^ ^10,^ ^11,^ ^13,^ ^14,^ ^17,^ ^18,^ ^21^ – ^24,^ ^27,^ ^28,^ ^34,^ ^35,^ ^38,^ ^40^ – ^43,^ ^45,^ ^52,^ ^53,^ ^55,^ ^57,^ ^61^ – ^66,^ ^73,^ ^76,^ ^82^
Unit of analysis same as unit of allocation | 7.1 | 2.9 | 3.7 | 0.8
| [2.6, 13.9] | [1.0, 7.0] | [0.0, 6.7] | [-0.5, 2.1]
| N = 21 ^1,^ ^9,^ ^10,^ ^14,^ ^22^ – ^24,^ ^28,^ ^30,^ ^38,^ ^40^ – ^42,^ ^45,^ ^53,^ ^55,^ ^57,^ ^62,^ ^65,^ ^73,^ ^82^ | N = 12 ^4,^ ^13,^ ^17,^ ^18,^ ^21,^ ^27,^ ^43,^ ^51,^ ^60,^ ^64,^ ^68,^ ^74^ | N = 29 ^1,^ ^7,^ ^9^ – ^11,^ ^14,^ ^22^ – ^24,^ ^26,^ ^28,^ ^30,^ ^34,^ ^35,^ ^38,^ ^40^ – ^42,^ ^45,^ ^52,^ ^53,^ ^55,^ ^57,^ ^61,^ ^62,^ ^65,^ ^73,^ ^76,^ ^82^ | N = 14 ^4,^ ^13,^ ^17,^ ^18,^ ^21,^ ^27,^ ^43,^ ^51,^ ^60,^ ^63,^ ^64,^ ^66,^ ^68,^ ^74^
Concealment allocation | 3.8 | 6.8 | 1.5 | 2.1
| [1.5, 9.6] | [1.7, 11.8] | [0.0, 4.7] | [-0.3, 5.0]
| N = 11 ^13,^ ^21,^ ^24,^ ^41,^ ^43,^ ^60,^ ^62,^ ^64,^ ^68,^ ^73,^ ^74^ | N = 22 ^1,^ ^4,^ ^9,^ ^10,^ ^14,^ ^17,^ ^18,^ ^22,^ ^23,^ ^27,^ ^28,^ ^30,^ ^38,^ ^40,^ ^42,^ ^45,^ ^51,^ ^53,^ ^55,^ ^57,^ ^65,^ ^82^ | N = 14 ^11,^ ^13,^ ^21,^ ^24,^ ^26,^ ^41,^ ^43,^ ^60^ – ^62,^ ^64,^ ^68,^ ^73,^ ^74^ | N = 29 ^1,^ ^4,^ ^7,^ ^9,^ ^10,^ ^14,^ ^17,^ ^18,^ ^22,^ ^23,^ ^27,^ ^28,^ ^30,^ ^34,^ ^35,^ ^38,^ ^40,^ ^42,^ ^45,^ ^51^ – ^53,^ ^55,^ ^57,^ ^63,^ ^65,^ ^66,^ ^76,^ ^82^
Total (i.e., irrespective of design feature presence or absence) | 4.5 | | 2.1
| [1.5, 11.0] | | [-0.2, 5.0]
| N = 33 ^1,^ ^4,^ ^9,^ ^10,^ ^13,^ ^14,^ ^17,^ ^18,^ ^21^ – ^24,^ ^27,^ ^28,^ ^30,^ ^38,^ ^40^ – ^43,^ ^45,^ ^51,^ ^53,^ ^55,^ ^57,^ ^60,^ ^62,^ ^64,^ ^65,^ ^68,^ ^73,^ ^74,^ ^82^ | | N = 43 ^1,^ ^4,^ ^7,^ ^9^ – ^11,^ ^13,^ ^14,^ ^17,^ ^18,^ ^21^ – ^24,^ ^26^ – ^28,^ ^30,^ ^34,^ ^35,^ ^38,^ ^40^ – ^43,^ ^45,^ ^51^ – ^53,^ ^55,^ ^57,^ ^60^ – ^66,^ ^68,^ ^73,^ ^74,^ ^76,^ ^82^

* In this table, all design features whose presence was judged as “unclear” were coded as absent.

† When N = 2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

Table 10b Association of methodologic features* with increased percentage of patients in blood pressure target range

| Median increase in proportion of patients in target SBP range | | Median increase in proportion of patients in target DBP range
| [inter-quartile range] ^†^ | | [inter-quartile range] ^†^
| N = Number of comparisons | | N = Number of comparisons
| Design feature present | Design feature absent | Design feature present | Design feature absent
RCT | 28.3 | 13.6 | 3.5 | 16.2
| [10.3, 36.6] | [11.8, 15.0] | [1.2, 8.8] | [7.1, 22.9]
| N = 10 ^12,^ ^13,^ ^16,^ ^19,^ ^25,^ ^45,^ ^53,^ ^67,^ ^72,^ ^78^ | N = 4 ^4,^ ^8,^ ^14,^ ^21^ | N = 10 ^7,^ ^15,^ ^26,^ ^38,^ ^60,^ ^61,^ ^68,^ ^69,^ ^74,^ ^79^ | N = 6 ^4,^ ^14,^ ^21,^ ^29,^ ^54,^ ^58^
Providers blinded | NA | 16.2 | NA | 6.0
| N = 0 | [10.3, 32.2] | N = 0 | [1.5, 17.5]
| | N = 14 ^4,^ ^8,^ ^12^ – ^14,^ ^16,^ ^19,^ ^21,^ ^25,^ ^45,^ ^53,^ ^67,^ ^72,^ ^78^ | | N = 16 ^4,^ ^7,^ ^14,^ ^15,^ ^21,^ ^26,^ ^29,^ ^38,^ ^54,^ ^58,^ ^60,^ ^61,^ ^68,^ ^69,^ ^74,^ ^79^
Patients blinded | -1.4 | 25.0 | 5.0 | 13.4
| [-3.6, 6.3] | [12.7, 35.2] | [1.8, 6.0] | [1.1, 19.0]
| N = 3 ^4,^ ^25,^ ^67^ | N = 11 ^8,^ ^12^ – ^14,^ ^16,^ ^19,^ ^21,^ ^45,^ ^53,^ ^72,^ ^78^ | N = 7 ^4,^ ^25,^ ^58,^ ^60,^ ^68,^ ^69,^ ^74^ | N = 9 ^7,^ ^14,^ ^15,^ ^21,^ ^29,^ ^38,^ ^54,^ ^61,^ ^79^
Unit of analysis same as unit of allocation | 20.7 | 16.2 | 9.4 | 5.0
| [9.0, 31.8] | [12.4, 34.8] | [1.1, 19.0] | [3.5, 10.2]
| N = 4 ^12,^ ^14,^ ^45,^ ^53^ | N = 10 ^4,^ ^8,^ ^13,^ ^16,^ ^19,^ ^21,^ ^25,^ ^67,^ ^72,^ ^78^ | N = 9 ^7,^ ^14,^ ^15,^ ^26,^ ^29,^ ^38,^ ^61,^ ^69,^ ^79^ | N = 7 ^4,^ ^21,^ ^54,^ ^58,^ ^60,^ ^68,^ ^74^
Concealment allocation | 13.4 | 18.6 | 5.0 | 9.4
| [9.7, 38.0] | [13.8, 31.6] | [1.6, 13.4] | [3.1, 21.6]
| N = 9 ^12,^ ^13,^ ^16,^ ^19,^ ^21,^ ^25,^ ^67,^ ^72,^ ^78^ | N = 5 ^4,^ ^8,^ ^14,^ ^45,^ ^53^ | N = 9 ^15,^ ^21,^ ^26,^ ^60,^ ^61,^ ^68,^ ^69,^ ^74,^ ^79^ | N = 7 ^4,^ ^7,^ ^14,^ ^29,^ ^38,^ ^54,^ ^58^
Total (i.e., irrespective of design feature presence or absence) | 16.2 | | 6.0
| [10.3, 32.2] | | [1.5, 17.5]
| N = 14 ^4,^ ^8,^ ^12^ – ^14,^ ^16,^ ^19,^ ^21,^ ^25,^ ^45,^ ^53,^ ^67,^ ^72,^ ^78^ | | N = 16 ^4,^ ^7,^ ^14,^ ^15,^ ^21,^ ^26,^ ^29,^ ^38,^ ^54,^ ^58,^ ^60,^ ^61,^ ^68,^ ^69,^ ^74,^ ^79^

* In this table, all design features whose presence was judged as “unclear” were coded as absent.

† When N = 2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

After stratifying studies by study design (RCT versus non-RCT), we analyzed the effect of individual QI strategies on blood pressure outcomes, comparing studies that included a particular QI strategy with those that did not include that particular QI strategy (e.g., studies with provider education versus studies without a provider education component) (see Table 11). Overall, the median reduction in SBP in RCTs was 6.8 mmHg (compared with 4.5 mmHg when both CBAs and RCTs are included, or 4.3 mmHg for non-RCTs), and median reduction in DBP was 2.0 mmHg (compared with 2.1 mmHg when both CBA and RCTs are included, or 2.7 mmHg for non-RCTs). In general, analysis of categories of QI strategies according to study type revealed zero or minimal change in median reduction in SBP and DBP effects. For example, when analyzing RCT studies alone, the effect of organizational change on median reduction in SBP was 11.0 mmHg (IQ range: 5.2, 16.2), in contrast with a reduction of 10.1 mmHg (IQ range: 3.9, 14.0) seen with all study types (19 comparisons). The largest magnitude change for study type substratified by QI strategy was for RCT comparisons reporting provider reminders, with a median reduction in SBP of 3.0 mmHg (IQ range: -0.8, 6.8), in contrast to a reduction of 6.8 mmHg (IQ range: 3.0, 9.4) seen with all studies. However, there were very few studies (three comparisons overall, and two RCTs) reporting the effect of use of provider reminders on reduction of SBP. ^113,^ ^122,^ ^153^

Table 11 Comparison of study design by quality improvement strategy on blood pressure outcomes

| Median Reduction in SBP (mmHg) | | | Median Improvement in DBP (mmHg)
| [inter-quartile range*] | | | [inter-quartile range*]
| N = Number of comparisons | | | N = Number of comparisons
| All Comparisons | RCT | Non-RCT^†^ | All Comparisons | RCT | Non-RCT
All QI types | 4.5 | 6.8 | 4.3 | 2.1 | 2.0 | 2.7
| [1.5, 11.0] | [1.5, 13.0] | [3.1, 8.1] | [-0.2, 5.0] | [0.0, 5.0] | [-0.9, 4.6]
| N = 33 | N = 25 | N = 8 | N = 43 | N = 33 | N = 10
Provider education | 2.7 | 2.0 | 3.8 | 0.7 | 0.6 | 3.3
| [1.1, 6.0] | [0.3, 5.1] | [2.4, 5.8] | [-0.3, 3.3] | [0.1, 1.3] | [-0.6, 3.8]
| N = 10 | N = 7 | N = 3 | N = 13 | N = 8 | N = 5
No provider education | 8.2 | 10.1 | 4.5 | 2.5 | 2.8 | 2.1
| [2.8, 13.7] | [2.6, 14.1] | [4.0, 9.3] | [-0.1, 6.4] | [0.0, 6.7] | [-1.0, 5.0]
| N = 22 | N = 17 | N = 5 | N = 30 | N = 25 | N = 5
Provider reminders | 6.8 | 3.0 | 12.0 | 2.1 | 0.9 | 11.0
| [3.0, 9.4] | [-0.8, 6.8] | | [0.9, 6.6] | [-0.3, 2.1]
| N = 3 | N = 2 | N = 1 | N = 3 | N = 2 | N = 1
No provider reminders | 4.3 | 6.9 | 4.0 | 2.1 | 2.0 | 2.1
| [1.6, 10.8] | [1.8, 13.5] | [2.4, 6.1] | [-0.2, 5.0] | [0.0, 5.3] | [-1.0, 3.8]
| N = 30 | N = 23 | N = 7 | N = 40 | N = 31 | N = 9
Facilitated relay | 5.7 | 6.9 | 4.5 | 1.1 | 1.6 | -1.0
| [2.4, 11.8] | [2.3, 13.0] | [4.0, 9.3] | [-1.0, 3.4] | [-0.1, 3.9] | [-1.6, 2.1]
| N = 18 | N = 13 | N = 5 | N = 20 | N = 15 | N = 5
No facilitated relay | 3.8 | 5.1 | 3.8 | 3.7 | 2.9 | 3.8
| [-0.9, 8.9] | [-0.8, 11.1] | [1.4, 5.8] | [0.2, 5.0] | [0.1, 5.5] | [3.3, 4.8]
| N = 15 | N = 12 | N = 3 | N = 23 | N = 18 | N = 5
Patient education | 8.1 | 8.1 | 6.6 | 3.3 | 2.8 | 3.5
| [3.3, 11.8] | [3.3, 12.5] | [2.6, 10.0] | [0.4, 5.0] | [-0.3, 5.9] | [2.4, 4.7]
| N = 18 | N = 14 | N = 4 | N = 25 | N = 19 | N = 6
No patient education | 2.6 | 2.3 | 4.3 | 0.6 | 0.8 | -1.3
| [1.2, 7.3] | [1.2, 10.5] | [3.3, 5.3] | [-0.3, 3.5] | [0.0, 3.5] | [-1.7, 0.5]
| N = 15 | N = 11 | N = 4 | N = 18 | N = 14 | N = 4
Self-management | 3.6 | 3.3 | 6.6 | 2.1 | 2.1 | 2.9
| [2.1, 9.5] | [1.0, 9.3] | [38, 9.3] | [0.4, 5.0] | [0.1, 5.9] | [2.1, 3.8]
| N = 12 | N = 10 | N = 2 | N = 17 | N = 15 | N = 2
No self-management | 6.8 | 7.1 | 4.3 | 1.5 | 1.5 | 1.3
| [1.5, 12.0] | [1.7, 13.6] | [1.8, 6.9] | [-0.5, 5.0] | [0.0, 4.9] | [-1.2, 4.9]
| N = 21 | N = 15 | N = 6 | N = 26 | N = 18 | N = 8
Patient reminders | 2.8 | 2.8 | 1.8 | 0.5 | 0.5 | 1.7
| [-1.5, 5.1] | [-1.7, 6.0] | [-1.0, 4.5] | [-2.1, 3.4] | [-2.3, 2.5] | [-1.6, 5.0]
| N = 8 | N = 6 | N = 2 | N = 12 | N = 10 | N = 2
No patient reminders | 7.1 | 7.1 | 5.9 | 2.1 | 2.1 | 2.7
| [2.0, 12.0] | [1.7, 13.5] | [3.9, 8.9] | [0.0, 5.0] | [0.3, 5.3] | [-0.7, 4.1]
| N = 25 | N = 19 | N = 6 | N = 31 | N = 23 | N = 8
Audit and feedback | 1.5 | 1.5 | - - - - | 0.5 | 0.5 | - - - -
| [1.3, 1.8] | [1.3, 1.8] | - - - - | [0.5, 1.0] | [0.5, 1.0] | - - - -
| N = 3 | N = 3 | N = 0 | N = 4 | N = 4 | N = 0
No audit and feedback | 6.9 | 7.0 | 4.3 | 2.1 | 2.1 | 2.7
| [2.4, 11.8] | [2.4, 13.7] | [3.1, 8.1] | [-0.5, 5.0] | [-0.1, 5.6] | [-0.9, 4.6]
| N = 30 | N = 22 | N = 8 | N = 39 | N = 29 | N = 10
Organizational change | 10.1 | 11.0 | 6.9 | 4.4 | 4.4 | 3.6
| [3.9, 14.0] | [5.2, 16.2] | [3.1, 10.0] | [-0.5, 6.9] | [-0.5, 6.9] | [1.2, 6.5]
| N = 19 | N = 15 | N = 4 | N = 23 | N = 19 | N = 4
No organizational change | 2.3 | 1.8 | 3.9 | 0.6 | 0.6 | 1.4
| [1.0, 4.0] | [0.6, 3.1] | [3.1, 4.9] | [-0.2, 2.1] | [0.1, 1.9] | [-0.9, 3.7]
| N = 14 | N = 10 | N = 4 | N = 20 | N = 14 | N = 6
Financial incentives | -13.3 | -13.3 | - - - - | 0.0 | 0.0 | - - - -
| | | - - - - | [-2.0, 2.5] | [-2.0, 2.5] | - - - -
| N = 1 | N = 1 | - - - - | N = 3 | N = 3 | N = 0
No financial incentives | 5.6 | 6.8 | 4.3 | 2.1 | 2.1 | 2.7
| [1.9, 11.3] | [1.9, 13.2] | [3.1, 8.1] | [-0.2, 5.0] | [0.1, 5.5] | [-0.9, 4.6]
| N = 32 | N = 24 | N = 8 | N = 40 | N = 30 | N = 10
Information systems | 2.2 | 2.2 | 2.8 | 0.6 | 0.7 | -1.8
| [1.1, 4.2] | [1.4, 4.7] | [1.9, 3.6] | [-1.3, 2.1] | [0.0, 2.1] | [-1.6, -2.0]
| N = 10 | N = 8 | N = 2 | N = 11 | N = 9 | N = 2
No information systems | 7.1 | 7.1 | 5.9 | 3.0 | 2.5 | 3.5
| [3.0, 12.5] | [2.6, 13.9] | [3.9, 8.9] | [0.0, 5.2] | [0.0, 5.9] | [1.4, 4.9]
| N = 23 | N = 17 | N = 6 | N = 32 | N = 24 | N = 8

* When N = 2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

† Includes 6 publications (with 7 comparisons) that are quasi-RCTs ^3,^ ^8,^ ^9,^ ^17,^ ^43,^ ^58,^ ^64^ and 9 publications (with 11 comparisons)that are controlled before-after studies. ^2,^ ^4,^ ^14,^ ^20,^ ^21,^ ^29,^ ^36,^ ^54,^ ^63,^ ^65,^ ^66^

Visual examination of Table 11 reveals that studies that included either organizational change (alone or in combination with other strategies) or patient education (in combination with other strategies) consistently report greater improvements in SBP and DBP, regardless of study design, as compared with studies without these particular strategies. Studies without patient reminders or provider audit and feedback (either alone or in combination) are similarly consistent in having greater improvements in SBP and DBP as compared with studies that included these strategies. For studies with other strategies, the results are less consistent by both outcome and study design.

### Effect of Methodologic Features on Provider and Patient Adherence to Recommendations

Eight studies (10 comparisons) assessed provider adherence to some aspect of recommended care of hypertensive patients. The majority of these studies were RCTs (see Table 10c). Studies having positive design features had greater improvements in provider adherence to recommended practice, but the inter-quartile ranges had substantial overlap, and Mann-Whitney tests did not show any significant differences by design feature. Because of the limited number of studies, we did not assess QI strategies by design feature for provider adherence outcomes.

Table 10c Association of methodologic features* with summary adherence outcomes

| Median improvement in proportion of provider adherence to recommended practice | | Median improvement in proportion of patient adherence
| [inter-quartile range] ^†^ | | [inter-quartile range] ^†^
| N = Number of comparisons | | N = Number of comparisons
| Design feature present | Design feature absent | Design feature present | Design feature absent
RCT | 2.3 | 5.0 | 1.90 | 7.3
| [-0.5, 3.7] | [2.6, 6.8] | [-0.38, 2.35] | [5.15, 9.45]
| N = 6 ^10,^ ^25,^ ^26,^ ^44,^ ^67,^ ^69^ | N = 4 ^3,^ ^4,^ ^20,^ ^58^ | N = 3 ^22,^ ^45,^ ^69^ | N = 2 ^4,^ ^8^
Providers blinded | NA | 3.0 | NA | 2.8
| N = 0 | [1.0, 5.5] | N = 0 | [1.9, 3.0]
| | N = 10 ^3,^ ^4,^ ^10,^ ^20,^ ^25,^ ^26,^ ^44,^ ^58,^ ^67,^ ^69^ | | N = 5 ^4,^ ^8,^ ^22,^ ^45,^ ^69^
Patients blinded | 3.3 | 2.0 | 0.17 | 2.8
| [0.6, 6.0] | N = 1 ^10^ | [-1.25, 1.59] | [2.35, 7.2]
| N = 9 ^3,^ ^4,^ ^20,^ ^25,^ ^26,^ ^44,^ ^58,^ ^67,^ ^69^ | | N = 2 ^4,^ ^69^ | N = 3 ^8,^ ^22,^ ^45^
Unit of analysis same as unit of allocation | 4.0 | 2.7 | 1.9 | 7.3
| [3.0, 5.0] | [-0.4, 5.0] | [-0.38, 2.35] | [5.15, 9.45]
| N = 3 ^10,^ ^26,^ ^69^ | N = 7 ^3,^ ^4,^ ^20,^ ^25,^ ^44,^ ^58,^ ^67^ | N = 3 ^22,^ ^45,^ ^69^ | N = 2 ^4,^ ^8^
Concealment allocation | 3.3 | 2.7 | -2.66 | 2.9
| [-1.3, 4.0] | [2.0, 6.7] | N = 1 ^69^ | [2.58, 5.15]
| N = 5 ^3,^ ^25,^ ^26,^ ^67,^ ^69^ | N = 5 ^4,^ ^10,^ ^20,^ ^44,^ ^58^ | | N = 4 ^4,^ ^8,^ ^22,^ ^45^
Total (i.e., irrespective of design feature presence or absence) | 3.0 | | 2.8
| [1.0, 5.5] | | [1.9, 3.0]
| N = 10 ^3,^ ^4,^ ^10,^ ^20,^ ^25,^ ^26,^ ^44,^ ^58,^ ^67,^ ^69^ | | N = 5 ^4,^ ^8,^ ^22,^ ^45,^ ^69^

* In this table, all design features whose presence was judged as “unclear” were coded as absent.

† When N = 2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

Only four studies (five comparisons) assessed patient adherence. Of these, three were RCTs and two were not (see Table 10c). Because of the small numbers of studies, the point estimates would have been imprecise, so we did not assess the impact of methodologic quality on patient adherence outcomes.

### Effect of Study Size on Blood Pressure Outcomes

Table 12a reports the association of sample size with SBP outcomes. Results are shown for studies that include each QI strategy, followed by studies that do not include that QI strategy. The studies with the smaller sample sizes appear to report larger effects on reduction in SBP. The Spearman rank correlation of effect size with sample size is 0.43 for SBP (P = 0.01). Table 12b shows a similar analysis for reduction in DBP. Again, the smaller studies appear to report larger effects, although this is not as pronounced. The Spearman rank correlation of effect size with sample size for DBP is 0.23 (P = 0.14). To explore possible confounding of sample size with study design, we estimated the Spearman rank correlation separately for trials that had the desirable study design feature of unit of analysis equal to unit of randomization, and for studies that did not have this design feature. For studies without this desirable design feature, the Spearman rank correlation of effect size with sample size for SBP was 0.02 (P = 0.53, N = 12), indicating no correlation, and -0.36 (P = 0.21, N = 14) for DBP, indicating larger effects for larger sample size studies. Since these studies require adjustments to sample size to account for patient clustering, the more appropriate Spearman rank correlation comparison is between effect size and effective study sample size (Appendix H), which for SBP is 0.01 (P = 0.97), and for DBP is 0.07 (P = 0.83), indicating no correlation after adjustments to sample size. In contrast, for studies in which the unit of randomization is the same as the unit of analysis, the correlations between sample size and effect size persisted, with a correlation of 0.58 (P = 0.006, N = 21) for SBP, and 0.40 (P = 0.030, N = 29) for DBP. Thus, the studies with differing unit of analysis and unit of randomization do not appear to be responsible for the correlations between study size and effect size for SBP and DBP; thus analysis by quartile of actual sample size is adequate. Also, non-RCT studies did not have a correlation between study size and effect size.

Table 12a Association of study size with systolic blood pressure outcomes

| Median Reduction in SBP (mmHg)
| [inter-quartile range]*
| N = Number of comparisons
| All Comparisons | Comparisons with sample size in lowest quartile | Comparisons with sample size in lower 2 quartiles | Comparisons with sample size in upper 2 quartiles | Comparisons with sample size in highest quartile
All QI types | 4.5 | 14.0 | 11.1 | 3.3 | 3.3
| [1.5, 11.0] | [12.3, 19.2] | [5.7, 15.2] | [1.0, 4.5] | [2.3, 4.5]
| N = 33 | N = 8 | N = 16 | N = 17 | N = 9
Provider education | 2.7 | 9.0 | 2.0 | 3.3 | 3.6
| [1.1, 6.0] | | [0.5, 5.5] | [1.2, 5.3] | [2.9, 4.8]
| N = 10 | N = 1 | N = 3 | N = 7 | N = 4
No provider education | 7.1 | 14.1 | 13.0 | 3.0 | 3.3
| [2.5, 13.5] | [13.5, 19.8] | [9.3, 18.3] | [0.9, 4.4] | [2.3, 4.5]
| N = 23 | N = 7 | N = 13 | N = 10 | N = 5
Provider reminders | 6.8 | - - - - | 12.0 | 3.0 | - - - -
| [3.0, 9.4] | - - - - | | [-0.8, 6.8] | - - - -
| N = 3 | N = 0 | N = 1 | N = 2 | N = 0
No provider reminders | 4.3 | 14.0 | 10.1 | 3.3 | 3.3
| [1.6, 10.8] | [12.3, 19.2] | [4.5, 16.2] | [1.3, 4.3] | [2.3, 4.5]
| N = 30 | N = 8 | N = 15 | N = 15 | N = 9
Facilitated relay | 5.7 | 13.5 | 10.7 | 3.0 | 3.3
| [2.4, 11.8] | [12.0, 16.8] | [7.4, 13.7] | [2.0, 4.1] | [2.8, 3.9]
| N = 18 | N = 4 | N = 10 | N = 8 | N = 3
No facilitated relay | 3.8 | 16.4 | 12.1 | 3.3 | 3.6
| [-0.9, 8.9] | [13.1, 19.2] | [1.8, 17.5] | [-0.8, 6.8] | [1.9, 6.3]
| N = 15 | N = 4 | N = 6 | N = 9 | N = 6
Patient education | 8.1 | 13.0 | 11.1 | 3.3 | 3.3
| [3.3, 11.8] | [10.1, 13.9] | [9.1, 13.7] | [0.1, 4.6] | [3.3, 3.8]
| N = 18 | N = 5 | N = 10 | N = 8 | N = 5
No patient education | 2.6 | 18.6 | 8.1 | 2.6 | 3.4
| [1.2, 7.3] | [16.4, 19.8] | [1.3, 17.5] | [1.5, 4.5] | [2.1, 5.3]
| N = 15 | N = 3 | N = 6 | N = 9 | N = 4
Self-management | 3.6 | 13.9 | 9.7 | 3.0 | 3.3
| [2.1, 9.5] | [12.0, 19.8] | [7.5, 13.0] | [1.0, 3.3] | [3.3, 3.6]
| N = 12 | N = 3 | N = 6 | N = 6 | N = 3
No self-management | 6.8 | 14.1 | 12.5 | 4.0 | 3.4
| [1.5, 12.0] | [13.0, 18.6] | [3.8, 17.3] | [1.2, 7.0] | [1.7, 6.5]
| N = 21 | N = 5 | N = 10 | N = 11 | N = 6
Patient reminders | 2.8 | - - - - | 6.9 | 2.3 | 2.8
| [-1.5, 5.1] | - - - - | [-3.2, 12.6] | [-1.0, 3.3] | [1.5, 3.6]
| N = 8 | N = 0 | N = 3 | N = 5 | N = 4
No patient reminders | 7.1 | 14.0 | 12.0 | 3.6 | 3.8
| [2.0, 12.0] | [12.3, 19.2] | [9.0, 14.1] | [1.4, 6.9] | [3.3, 7.1]
| N = 25 | N = 8 | N = 13 | N = 12 | N = 5
Audit and feedback | 1.5 | - - - - | 1.5 | 1.5 | 1.5
| [1.3, 1.8] | - - - - | [1.0, 2.0]
| N = 3 | N = 0 | N = 2 | N = 1 | N = 1
No audit and feedback | 6.9 | 14.0 | 12.5 | 3.3 | 3.6
| [2.4, 11.8] | [12.3, 19.2] | [9.1, 17.3] | [0.9, 5.1] | [31, 5.2]
| N = 30 | N = 8 | N = 14 | N = 16 | N = 8
Organizational change | 10.1 | 14.0 | 13.5 | 3.3 | 3.3
| [3.9, 14.0] | [12.3, 19.2] | [9.9, 18.4] | [0.7, 5.8] | [2.3, 4.5]
| N = 19 | N = 8 | N = 12 | N = 7 | N = 5
No organizational change | 2.3 | - - - - | 1.5 | 3.0 | 3.6
| [1.0, 4.0] | - - - - | [0.5, 3.2] | [1.1, 4.0] | [2.9, 4.8]
| N = 14 | N = 0 | N = 4 | N = 10 | N = 4
Financial incentives | -13.3 | - - - - | -13.3 | - - - - | - - - -
| | - - - - | | - - - - | - - - -
| N = 1 | N = 0 | N = 1 | N = 0 | N = 0
No financial incentives | 5.6 | 14.0 | 12.0 | 3.3 | 3.3
| [1.9, 11.3] | [12.3, 19.2] | [8.0, 16.2] | [1.0, 4.5] | [2.3, 4.5]
| N = 32 | N = 8 | N = 15 | N = 17 | N = 9
Information systems | 2.2 | 17.3 | 5.5 | 1.9 | 2.8
| [1.1, 4.2] | [9.0, 25.7] | [1.8, 13.2] | [1.1, 3.1] | [2.1, 3.6]
| N=10 | N=2 | N=4 | N=6 | N=4
No information systems | 7.1 | 14.0 | 12.5 | 3.8 | 3.8
| [3.0, 12.5] | [13.2, 17.5] | [8.7, 15.2] | [0.9, 7.0] | [3.3, 7.1]
| N=23 | N=6 | N=12 | N=11 | N=5

* When N = 2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

Table 12b Association of study size with diastolic blood pressure outcomes

| Median Reduction in DBP (mmHg)
| [inter-quartile range]*
| N = Number of comparisons
| All Comparisons | Comparisons with sample size in lowest quartile | Comparisons with sample size in lower 2 quartiles | Comparisons with sample size in upper 2 quartiles | Comparisons with sample size in highest quartile
All QI types | 2.1 | 5.0 | 2.1 | 1.9 | 3.3
| [-0.2, 5.0] | [1.4, 10.7] | [0.0, 7.0] | [-0.9, 3.8] | [-0.3, 4.1]
| N = 43 | N = 11 | N = 21 | N = 22 | N = 11
Provider education | 0.7 | -0.2 | 0.3 | 2.1 | 3.5
| [-0.3, 3.3] | [-0.6, 0.3] | [-0.3, 0.8] | [-0.3, 3.7] | [1.3, 3.8]
| N = 13 | N = 2 | N = 4 | N = 9 | N = 6
No provider education | 2.5 | 6.7 | 5.0 | 1.6 | 0.0
| [-0.1, 6.4] | [4.0, 12.5] | [0.6, 9.0] | [-1.0, 4.4] | [-1.6, 4.4]
| N = 30 | N = 9 | N = 17 | N = 13 | N = 5
Provider reminders | 2.1 | ——— | 11.0 | 0.9 | - - - -
| [0.9, 6.6] | ——— | | [-0.3, 2.1] | - - - -
| N = 3 | N = 0 | N = 1 | N = 2 | N = 0
No provider reminders | 2.1 | 5.0 | 2.1 | 1.9 | 3.3
| [-0.2, 5.0] | [2.1, 10.7] | [0.3, 7.0] | [-1.0, 4.0] | [0.3, 4.1]
| N = 40 | N = 11 | N = 20 | N = 20 | N = 11
Facilitated relay | 1.1 | 2.1 | 2.0 | -1.0 | -2.0
| [-1.0, 3.4] | [1.3, 7.0] | [0.4, 7.5] | [-1.7, 1.7] | [-2.4, -1.6]
| N = 20 | N = 7 | N = 12 | N = 8 | N = 2
No facilitated relay | 3.7 | 10.8 | 4.0 | 3.5 | 3.7
| [0.2, 5.0] | [6.0, 15.5] | [0.4, 7.0] | [0.1, 4.7] | [0.6, 4.4]
| N = 23 | N = 4 | N = 9 | N = 14 | N = 9
Patient education | 3.3 | 5.9 | 5.0 | 3.0 | 3.7
| [0.4, 5.0] | [2.8, 8.4] | [0.4, 7.0] | [1.0, 4.0] | [3.4, 4.3]
| N = 25 | N = 6 | N = 13 | N = 12 | N = 6
No patient education | 0.6 | 4.0 | 1.5 | 0.1 | 0.0
| [-0.3, 3.5] | [2.0, 14.8] | [0.5, 6.7] | [-1.5, 1.8] | [-1.6, 0.6]
| N = 18 | N = 5 | N = 8 | N = 10 | N = 5
Self-management | 2.1 | 7.9 | 1.3 | 2.8 | 3.8
| [0.4, 5.0] | [5.6, 9.9] | [0.0, 6.9] | [1.8, 3.7] | [37, 4.4]
| N = 17 | N = 4 | N = 10 | N = 7 | N = 3
No self-management | 1.5 | 4.0 | 4.0 | 0.0 | 0.3
| [-0.5, 5.0] | [1.3, 9.9] | [0.8, 9.0] | [-1.0, 3.8] | [-0.9, 3.6]
| N = 26 | N = 7 | N = 11 | N = 15 | N = 8
Patient reminders | 0.5 | - - - - | 0.5 | 0.0 | -2.0
| [-2.1, 3.4] | | [-2.8, 5.4] | [-1.9, 2.5] | [-2.4, -1.6]
| N = 12 | N = 0 | N = 6 | N = 6 | N = 2
No patient reminders | 2.1 | 5.0 | 4.0 | 2.1 | 3.7
| [0.0, 5.0] | [2.0, 10.7] | [0.8, 10.0] | [-0.4, 4.0] | [0.6, 4.4]
| N = 31 | N = 11 | N = 15 | N = 16 | N = 9
Audit and feedback | 0.6 | 1.3 | 0.7 | 0.6 | 0.6
| [0.5, 1.0] | [0.7, 2.0] | [0.3, 1.3]
| N = 4 | N = 2 | N = 3 | N = 1 | N = 1
No audit and feedback | 2.1 | 6.7 | 4.5 | 2.1 | 3.5
| [-0.5, 5.0] | [4.0, 12.0] | [0.5, 8.5] | [-1.0, 3.8] | [-0.5, 4.3]
| N = 39 | N = 9 | N = 18 | N = 21 | N = 10
Organizational change | 4.4 | 6.7 | 6.9 | 2.8 | 1.9
| [-0.5, 6.9] | [4.0, 12.5] | [3.5, 11.4] | [-1.3, 4.7] | [-1.2, 4.2]
| N = 23 | N = 9 | N = 12 | N = 11 | N = 6
No organizational change | 0.6 | 1.3 | 0.6 | 1.6 | 3.3
| [-0.2, 2.1] | [0.7, 2.0] | [0.0, 1.0] | [-0.5, 2.7] | [0.6, 3.8]
| N = 20 | N = 2 | N = 9 | N = 11 | N = 5
Financial incentives | 0.0 | - - - - | -3.9 | 2.5 | 2.5
| [-2.0, 2.5] | - - - - | | [0, 5.0] | [0, 5.0]
| N = 3 | N = 0 | N = 1 | N = 2 | N = 2
No financial incentives | 2.1 | 5.0 | 3.0 | 1.8 | 3.3
| [-0.2, 5.0] | [2.0, 10.7] | [0.5, 7.5] | [-1.0, 3.7] | [-0.6, 3.8]
| N = 40 | N = 11 | N = 20 | N = 20 | N = 9
Information systems | 0.6 | 1.3 | 0.7 | -0.5 | -0.5
| [-1.3, 2.1] | [0.3, 4.6] | [0.0, 2.0] | [-1.9, 1.7] | [-1.8, 1.4]
| N = 11 | N = 4 | N = 5 | N = 6 | N = 4
No information systems | 3.0 | 6.7 | 4.5 | 2.5 | 3.8
| [0.0, 5.2] | [4.5, 11.9] | [0.5, 7.5] | [-0.4, 4.5] | [1.6, 4.6]
| N = 32 | N = 7 | N = 16 | N = 16 | N = 7

* When N = 2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

Correlation analysis for SBP and DBP in target range did not show any significant results, though the magnitude of the rank correlation for SBP range was -0.37 (P = 0.21), indicating a similar trend toward larger studies having less improvement (lower proportion of patients in range compared with smaller studies).

Visual inspection of Tables 12a and 12b reveal a somewhat consistent pattern for specific QI strategies across both blood pressure outcomes, when considering sample size. For example, as reported earlier, studies that include organizational change have improvements in SBP of 10.1 mmHg, and in DBP of 4.4 mmHg, as compared with 2.3 mmHg and 0.6 mmHg, respectively, for studies without an organizational change component. For studies reporting SBP outcomes that are in the bottom half of study sample size, those that include organizational change (12 comparisons) show improvements in SBP of 13.5 mmHg, while those that do not include organizational change (four comparisons, none of which would fall into the bottom quartile of study sample size) show effectively no improvement in SBP (0.1 mmHg). For studies reporting SBP outcomes that are in the top half of study sample size, those that include organizational change (seven comparisons, including five in the largest study size quartile,) and those that do not (10 comparisons, including four in the largest study size quartile), have similar magnitude improvements (3.3 mmHg versus 3.6 mmHg). A similar trend of effect sizes eroding with study size is seen for DBP, though perhaps to a less striking degree, as the studies with organizational change still appear to show greater improvements in DBP as compared with studies without organizational change (2.8 mmHg versus 1.6 mmHg). For the largest study size quartile, however, the relative magnitudes of DBP outcomes reverse, which occurs for SBP outcomes as well.