# Table References

1 Ahring KK, Ahring JP, Joyce C, Farid NR. Telephone modem access improves diabetes control in those with insulin-requiring diabetes. Diabetes Care. Aug. 1992;15(8):971-975. [pmid: 1505329].
2 Albisser AM, Harris RI, Sakkal S, Parson ID, Chao SC. Diabetes intervention in the information age. Med Inform (Lond). Oct–Dec. 1996;21(4):297-316. [pmid: 9179834].
3 Aubert RE, Herman WH, Waters J, et al. Nurse case management to improve glycemic control in diabetic patients in a health maintenance organization. A randomized, controlled trial. Ann Intern Med. Oct 15. 1998;129(8):605-612. [pmid: 9786807].
4 Benjamin EM, Schneider MS, Hinchey KT. Implementing practice guidelines for diabetes care using problem-based learning. A prospective controlled trial using firm systems. Diabetes Care. Oct. 1999;22(10):1672-1678. [pmid: 10526733].
5 Boucher BJ, Claff HR, Edmonson M, et al. A pilot Diabetic Support Service based on family practice attenders: comparison with diabetic clinics in east London. Diabet Med. Sep–Oct. 1987;4(5):480-484. [pmid: 2959442].
6 Branger PJ, van't Hooft A, van der Wouden JC, Moorman PW, van Bemmel JH. Shared care for diabetes: supporting communication between primary and secondary care. Int J Med Inf. Feb–Mar. 1999;53(23):133-142.
7 Cagliero E, Levina EV, Nathan DM. Immediate feedback of HbA1c levels improves glycemic control in type 1 and insulin-treated type 2 diabetic patients. Diabetes Care. Nov. 1999;22(11):1785-1789. [pmid: 10546008].
8 Clancy DE, Brown SB, Magruder KM, Huang P. Group visits in medically and economically disadvantaged patients with type 2 diabetes and their relationships to clinical outcomes. Top Health Inf Manage. Jan–Mar. 2003;24(1):8-14. [pmid: 12674390].
9 Clifford RM, Batty KT, Davis TME, et al. A randomised controlled trial of a pharmaceutical care programme in high-risk diabetic patients in an outpatient clinic. International Journal of Pharmacy Practice. June. 2002;Vol 10(2):85-90.
10 Coffey E, Moscovice I, Finch M, Christianson JB, Lurie N. Capitated Medicaid and the process of care of elderly hypertensives and diabetics: results from a randomized trial. Am J Med. Jun. 1995;98(6):531-536. [pmid: 7778569].
11 Dargis V, Pantelejeva O, Jonushaite A, Vileikyte L, Boulton AJ. Benefits of a multidisciplinary approach in the management of recurrent diabetic foot ulceration in Lithuania: a prospective study. Diabetes Care. Sep. 1999;22(9):1428-1431. [pmid: 10480504].
12 de Sonnaville JJ, Bouma M, Colly LP, Deville W, Wijkel D, Heine RJ. Sustained good glycaemic control in NIDDM patients by implementation of structured care in general practice: 2-year follow-up study. Diabetologia. Nov. 1997;40(11):1334-1340. [pmid: 9389427].
13 Deeb LC, Pettijohn FP, Shirah JK, Freeman G. Interventions among primary-care practitioners to improve care for preventable complications of diabetes. Diabetes Care. Mar. 1988;11(3):275-280. [pmid: 3416683].
14 Feder G, Griffiths C, Highton C, Eldridge S, Spence M, Southgate L. Do clinical guidelines introduced with practice based education improve care of asthmatic and diabetic patients? A randomised controlled trial in general practices in east London. BMJ. Dec 2. 1995;311(7018):1473-1478. [pmid: 8520339]. [pmcid: 2543702].
15 Franz MJ, Monk A, Barry B, et al. Effectiveness of medical nutrition therapy provided by dietitians in the management of non-insulin-dependent diabetes mellitus: a randomized, controlled clinical trial. J Am Diet Assoc. Sept. 1995;95(9):1009-1017. [pmid: 7657902].
16 Frijling BD, Lobo CM, Hulscher ME, et al. Multifaceted support to improve clinical decision making in diabetes care: a randomized controlled trial in general practice. Diabet Med. Oct. 2002;19(10):836-842. [pmid: 12358871].
17 Gaede P, Vedel P, Larsen N, Jensen GV, Parving HH, Pedersen O. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. Jan 30. 2003;348(5):383-393. [pmid: 12556541].
18 Gaede P, Vedel P, Parving HH, Pedersen O. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. Feb 20. 1999;353(9153):617-622. [pmid: 10030326].
19 Ginsberg BH. Preliminary results of a disease state management program or diabetes. J Clin Outcomes Manage. 1996;3(4):45.
20 Glasgow RE, Toobert DJ, Hampson SE. Effects of a brief office-based intervention to facilitate diabetes dietary self-management. Diabetes Care. Aug. 1996;19(8):835-842. [pmid: 8842601].
21 Groeneveld Y, Petri H, Hermans J, Springer M, IN. An assessment of structured care assistance in the management of patients with type 2 diabetes in general practice. Scandinavian Journal of Primary Health Care. 2001/// 2001;Vol 19(1):30.
22 Hartmann, et al. Effects of peer-review groups on physicians' practice. Eur J Gen Pract. 1995;1:107.
23 Hayes TM, Harries J. Randomised controlled trial of routine hospital clinic care versus routine general practice care for type II diabetics. Br Med J (Clin Res Ed). Sep 22. 1984;289(6447):728-730.
24 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. Winter. 2000;16(1):210-227. [pmid: 10815366].
25 Hirsch IB, Goldberg HI, Ellsworth A, et al. A multifaceted intervention in support of diabetes treatment guidelines: a controlled trial. Diabetes Res Clin Pract. Oct. 2002;58(1):27-36. [pmid: 12161054].
26 Hoskins PL, Fowler PM, Constantino M, Forrest J, Yue DK, Turtle JR. Sharing the care of diabetic patients between hospital and general practitioners: does it work?. Diabet Med. Jan–Feb. 1993;10(1):81-86. [pmid: 8435994].
27 Hurwitz B, Goodman C, Yudkin J. Prompting the clinical care of non-insulin dependent (type II) diabetic patients in an inner city area: one model of community care. BMJ. Mar 6. 1993;306(6878):624-630. [pmid: 8461815]. [pmcid: 1676949].
28 Jaber LA, Halapy H, Fernet M, Tummalapalli S, Diwakaran H. Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother. Mar. 1996;30(3):238-243. [pmid: 8833557].
29 Kiefe CI, Allison JJ, Williams OD, Person SD, Weaver MT, Weissman NW. Improving quality improvement using achievable benchmarks for physician feedback: a randomized controlled trial. JAMA. Jun 13. 2001;285(22):2871-2879. [pmid: 11401608].
30 Kinmonth AL, Woodcock A, Griffin S, Spiegal N, Campbell MJ. Randomised controlled trial of patient centred care of diabetes in general practice: impact on current wellbeing and future disease risk. The Diabetes Care From Diagnosis Research Team. BMJ. Oct 31. 1998;317(7167):1202-1208. [pmid: 9794859].
31 Kogan JR, Reynolds EE, Shea JA. Effectiveness of report cards based on chart audits of residents' adherence to practice guidelines on practice performance: a randomized controlled trial. Teach Learn Med. Winter. 2003;15(1):25-30. [pmid: 12632705].
32 Legorreta. Effect of a comprehensive nurse-managed diabetes program: an HMO prospective study. Am.J Managed Care. 1996;2;1024–30, 1996. JC CP:30.
33 Levetan CS, Dawn KR, Robbins DC, Ratner RE. Impact of computer-generated personalized goals on HbA(1c). Diabetes Care. Jan. 2002;25(1):2-8. [pmid: 11772893].
34 Lim FS, Toh MP, Emmanuel SC, Chan SP, Lim G. A preliminary evaluation of a disease management programme for patients with diabetes mellitus and hypertension in a primary healthcare setting. Ann Acad Med Singapore. Jul. 2002;31(4):431-439. [pmid: 12161877].
35 Litzelman DK, Slemenda CW, Langefeld CD, et al. Reduction of lower extremity clinical abnormalities in patients with non-insulin-dependent diabetes mellitus. A randomized, controlled trial. Ann Intern Med. Jul 1. 1993;119(1):36-41. [pmid: 8498761].
36 Lobach DF, Hammond WE. Computerized decision support based on a clinical practice guideline improves compliance with care standards. Am J Med. Jan. 1997;102(1):89-98. [pmid: 9209205].
37 Mazzuca SA, Moorman NH, Wheeler ML, et al. The diabetes education study: a controlled trial of the effects of diabetes patient education. Diabetes Care. Jan–Feb. 1986;9(1):1-10. [pmid: 3948638].
38 McDermott RA, Schmidt BA, Sinha A, Mills P. Improving diabetes care in the primary healthcare setting: a randomised cluster trial in remote Indigenous communities. Med J Aust. May 21. 2001;174(10):497-502. [pmid: 11419768].
39 Meigs JB, Cagliero E, Dubey A, et al. A controlled trial of web-based diabetes disease management: the MGH diabetes primary care improvement project. Diabetes Care. Mar. 2003;26(3):750-757. [pmid: 12610033].
40 O'Connor PJ, Rush WA, Peterson J, et al. Continuous quality improvement can improve glycemic control for HMO patients with diabetes. Arch Fam Med. Oct. 1996;5(9):502-506. [pmid: 8930220].
41 Oh JA, Kim HS, Yoon KH, Choi ES. A telephone-delivered intervention to improve glycemic control in type 2 diabetic patients. Yonsei Med J. Feb. 2003;44(1):1-8. [pmid: 12619168].
42 Olivarius NF, Beck-Nielsen H, Andreasen AH, Horder M, Pedersen PA. Randomised controlled trial of structured personal care of type 2 diabetes mellitus. BMJ. Oct 27. 2001;323(7319):970-975. [pmid: 11679387]. [pmcid: 59690].
43 Ovhed I, Johansson E, Odeberg H, Rastam L. A comparison of two different team models for treatment of diabetes mellitus in primary care. Scand J Caring Sci. 2000;14(4):253-258. [pmid: 12035216].
44 Palmer RH, Louis TA, Hsu LN, et al. A randomized controlled trial of quality assurance in sixteen ambulatory care practices. Med Care. Jun. 1985;23(6):751-770. [pmid: 3892184].
45 Piette JD, Weinberger M, Kraemer FB, McPhee SJ. Impact of automated calls with nurse follow-up on diabetes treatment outcomes in a Department of Veterans Affairs Health Care System: a randomized controlled trial. Diabetes Care. Feb. 2001;24(2):202-208. [pmid: 11213866].
46 Piette JD, Weinberger M, McPhee SJ, Mah CA, Kraemer FB, Crapo LM. Do automated calls with nurse follow-up improve self-care and glycemic control among vulnerable patients with diabetes?. Am J Med. Jan. 2000;108(1):20-27. [pmid: 11059437].
47 Pouwer F, Snoek FJ, van der Ploeg HM, Ader HJ, Heine RJ. Monitoring of psychological well-being in outpatients with diabetes: effects on mood, HbA(1c), and the patient's evaluation of the quality of diabetes care: a randomized controlled trial. Diabetes Care. Nov. 2001;24(11):1929-1935. [pmid: 11679459].
48 Reed RL, Revel AO, Carter A, Saadi HF, Dunn EV. A clinical trial of chronic care diabetic clinics in general practice in the United Arab Emirates: a preliminary analysis. Arch Physiol Biochem. Jul. 2001;109(3):272-280. [pmid: 11880932].
49 Renders CM, Valk GD, Franse LV, et al. Long-term effectiveness of a quality improvement program for patients with type 2 diabetes in general practice. Diabetes Care. Aug. 2001;24(8):1365-1370. [pmid: 11473071].
50 Ronnemaa T, Hamalainen H, Toikka T, Liukkonen I. Evaluation of the impact of podiatrist care in the primary prevention of foot problems in diabetic subjects. Diabetes Care. Dec. 1997;20(12):1833-1837. [pmid: 9405902].
51 Sadur CN, Moline N, Costa M, et al. Diabetes management in a health maintenance organization. Efficacy of care management using cluster visits. Diabetes Care. Dec. 1999;22(12):2011-2017. [pmid: 10587835].
52 Smith SA, Murphy ME, Huschka TR, et al. Impact of a diabetes electronic management system on the care of patients seen in a subspecialty diabetes clinic. Diabetes Care. Jun. 1998;21(6):972-976. [pmid: 9614616].
53 Stroebel RJ, Scheitel SM, Fitz JS, et al. A randomized trial of three diabetes registry implementation strategies in a community internal medicine practice. Jt Comm J Qual Improv. Aug. 2002;28(8):441-450. [pmid: 12174408].
54 Thompson DM, Kozak SE, Sheps S. Insulin adjustment by a diabetes nurse educator improves glucose control in insulin-requiring diabetic patients: a randomized trial. CMAJ. Oct 19. 1999;161(8):959-962. [pmid: 10551191]. [pmcid: 1230704].
55 Vaughan NJ, Potts A. Implementation and evaluation of a decision support system for type II diabetes. Comput Methods Programs Biomed. Aug. 1996;50(3):247-251. [pmid: 8894384].
56 Wagner EH, Grothaus LC, Sandhu N, et al. Chronic care clinics for diabetes in primary care: a system-wide randomized trial. Diabetes Care. Apr. 2001;24(4):695-700. [pmid: 11315833].
57 Walker EA, Engel SS, Zybert PA, IN. Dissemination of diabetes care guidelines: lessons learned from community health centers. Diabetes Educator. Jan 2001;27(1):101–110.
58 Ward A, Kamien M, Mansfield F, Fatovich B. Educational feedback in the management of type 2 diabetes in general practice. Education for General Practice. 1996;7:142-150.
59 Weinberger M, Kirkman MS, Samsa GP, et al. A nurse-coordinated intervention for primary care patients with non-insulin-dependent diabetes mellitus: impact on glycemic control and health-related quality of life. J Gen Intern Med. Feb. 1995;10(2):59-66. [pmid: 7730940].
60 Integrated care for diabetes: clinical, psychosocial, and economic evaluation. Diabetes Integrated Care Evaluation Team. BMJ. May 7 1994;308(6938):1208–1212.