# Figure 1 References

1 Blonde L, Guthrie R, Testa M, et al. Diabetes management by a team of diabetes nurse educators, endocrinologists and primary care physicians in a managed care setting [abstract]. Book/Association for Health Services Research.16:318–319.
2 Shultz EK, Bauman A, Hayward M, Holzman R. Improved care of patients with diabetes through telecommunications. Ann N Y Acad Sci. 1992;670:141-145. [pmid: 1309083].
3 Nilasena DS, Lincoln MJ. A computer-generated reminder system improves physician compliance with diabetes preventive care guidelines. Proc Annu Symp Comput Appl Med Care. 1995:640–645.
4 Integrated care for diabetes: clinical, psychosocial, and economic evaluation. Diabetes Integrated Care Evaluation Team. BMJ. 1994;308:1208–1212.
5 Thompson FJ, Veves A, Ashe H, Boulton AJM, et al. A team approach to diabetic foot care: the Manchester experience. Foot. 1991;1:75-82.
6 Leese GP, Ahmed S, Newton RW, et al. Use of mobile screening unit for diabetic retinopathy in rural and urban areas. BMJ. 1993;306:187-189. [pmid: 8443485]. [pmcid: 1676588].