# References

1 National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention. Diabetes: disabling, deadly, and on the rise. Available at: http://www.cdc.gov/nccdphp/aag/pdf/aag_ddt2003.pdf. Accessed November 16, 2003.
2 Mokdad AH, Ford ES, Bowman BA, et al. Prevalence of obesity, diabetes, and obesity-related health risk factors, 2001. JAMA. 2003;289:76-79. [pmid: 12503980].
3 Narayan KM, Boyle JP, Thompson TJ, Sorensen SW, Williamson DF. Lifetime risk for diabetes mellitus in the United States. JAMA. 2003;290:1884-1890. [pmid: 14532317].
4 The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. N Engl J Med. 1993;329:977–986.
5 United Kingdom Prospective Diabetes Study (UKPDS). 13: Relative efficacy of randomly allocated diet, sulphonylurea, insulin, or metformin in patients with newly diagnosed non-insulin dependent diabetes followed for three years. BMJ. 1995;310:83-88. [pmid: 7833731]. [pmcid: 2548496].
6 Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet;1998;352:837–853.
7 Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. UK Prospective Diabetes Study Group. BMJ. 1998;317:703–713
8 Efficacy of atenolol and captopril in reducing risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 39. UK Prospective Diabetes Study Group. BMJ. 1998;317:713–720.
9 Pyorala K, Pedersen TR, Kjekshus J, Faergeman O, Olsson AG, Thorgeirsson G. Cholesterol lowering with simvastatin improves prognosis of diabetic patients with coronary heart disease. A subgroup analysis of the Scandinavian Simvastatin Survival Study (4S). Diabetes Care. 1997;20:614-620. [pmid: 9096989].
10 American Diabetes Association. Standards of medical care for patients with diabetes mellitus. Diabetes Care. 2003;26(Suppl 1):S33-50. [pmid: 12502618].
11 Stratton IM, Adler AI, Neil HA, et al. Association of glycaemia with macrovascular and microvascular complications of type 2 diabetes (UKPDS 35): prospective observational study. BMJ. 2000;321:405-412. [pmid: 10938048]. [pmcid: 27454].
12 The State of Health Care Quality: 2002. Available at: www.ncqa.org. 2003.
13 Saaddine JB, Engelgau MM, Beckles GL, Gregg EW, Thompson TJ, Narayan KM. A diabetes report card for the United States: quality of care in the 1990s. Ann Intern Med. 2002;136:565-574. [pmid: 11955024].
14 McFarlane SI, Jacober SJ, Winer N, et al. Control of cardiovascular risk factors in patients with diabetes and hypertension at urban academic medical centers. Diabetes Care. 2002;25:718-723. [pmid: 11919131].
15 Diabetes prevalence among American Indians and Alaska Natives and the overall population—United States, 1994-2002. MMWR Morb Mortal Wkly Rep. 2003;52:702–704.
16 Renders CM, Valk GD, Griffin S, Wagner EH, Eijk JT, Assendelft WJ. Interventions to improve the management of diabetes mellitus in primary care, outpatient and community settings. In: Cochrane Database Syst Rev, 1 Number, 2001. Chichester, UK: John Wiley & Sons, Ltd.
17 Weingarten SR, Henning JM, Badamgarav E, et al. Interventions used in disease management programmes for patients with chronic illness—which ones work? Meta-analysis of published reports. BMJ. 2002;325:925-933. [pmid: 12399340]. [pmcid: 130055].
18 National Diabetes Aliance. National Diabetes Quality Improvement Alliance Performance Measurement Set for Adult Diabetes. Available at: http://www.nationaldiabetesalliance.org/Final_03_Measures.pdf. Accessed November 16, 2003.
19 Sacks DB, Bruns DE, Goldstein DE, Maclaren NK, McDonald JM, Parrott M. Guidelines and recommendations for laboratory analysis in the diagnosis and management of diabetes mellitus. Clin Chem. 2002;48:436-472. [pmid: 11861436].
20 Bero LA, Grilli R, Grimshaw JM, Harvey E, Oxman AD, Thomson MA. Closing the gap between research and practice: an overview of systematic reviews of interventions to promote the implementation of research findings. The Cochrane Effective Practice and Organization of Care Review Group. BMJ. 1998;317:465-468. [pmid: 9703533]. [pmcid: 1113716].
21 Grimshaw J, McAuley LM, Bero LA, et al. Systematic reviews of the effectiveness of quality improvement strategies and programmes. Qual Saf Health Care. 2003;12:298-303. [pmid: 12897365]. [pmcid: 1743751].
22 Cochrane Effective Practice and Organisation of Care Group. EPOC Register. Available at: http://www.epoc.uottawa.ca/register.htm. Accessed November 17, 2003.
23 Balas EA, Boren SA, Griffing G. Computerized management of diabetes: a synthesis of controlled trials. Proc AMIA Symp. 1998:295–299.
24 Bloomgarden, et al. Randomized, controlled trial of diabetic patient education: improved knowledge without improved metabolic status. Diabetes Care. 1987;10:263. [pmid: 3297575].
25 Crawford MJ, Rutter D, Manley C, et al. Systematic review of involving patients in the planning and development of health care. BMJ. 2002;325:1263. [pmid: 12458240]. [pmcid: 136920].
26 D'Eramo-Melkus GA, Wylie-Rosett J, Hagan JA. Metabolic impact of education in NIDDM. Diabetes Care. 1992;15:864-869. [pmid: 1516506].
27 Dunn SM, Beeney LJ, Hoskins PL, Turtle JR. Knowledge and attitude change as predictors of metabolic improvement in diabetes education. Soc Sci Med. 1990;31:1135-1141. [pmid: 2274802].
28 Eakin EG, Bull SS, Glasgow RE, Mason M. Reaching those most in need: a review of diabetes self-management interventions in disadvantaged populations. Diabetes Metab Res Rev. 2002;18:26-35. [pmid: 11921415].
29 Gary TL, Genkinger JM, Guallar E, Peyrot M, Brancati FL. Meta-analysis of randomized educational behavioral interventions in type 2 diabetes. Diabetes Educ. 2003;29:488-501. [pmid: 12854339].
30 Greenfield S, Kaplan SH, Ware JE Jr, Yano EM, Frank HJ. Patients' participation in medical care: effects on blood sugar control and quality of life in diabetes. J Gen Intern Med. 1988;3:448-457. [pmid: 3049968].
31 Greenhalgh PM. Shared care for diabetes. A systematic review. Occas Pap R Coll Gen Pract. 1994:i–viii, 1–35.
32 Griffin S. Diabetes care in general practice: meta-analysis of randomised control trials. BMJ. 1998;317:390-396. [pmid: 9694757]. [pmcid: 28634].
33 Hunt DL, Haynes RB, Hanna SE, Smith K. Effects of computer-based clinical decision support systems on physician performance and patient outcomes: a systematic review. JAMA. 1998;280:1339-1346. [pmid: 9794315].
34 Krishna S, Balas EA, Spencer DC, Griffin JZ, Boren SA. Clinical trials of interactive computerized patient education: implications for family practice. J Fam Pract. 1997;45:25-33. [pmid: 9228910].
35 Lorenz RA, Pichert JW, Enns SJ, Hanson SL. Impact of organizational interventions on the delivery of patient education in a diabetes clinic. Patient Educ Couns. 1986;8:115-123. [pmid: 10277393].
36 Mitchell. Does primary medical practitioner involvement with a specialist team improve patient outcomes? A systematic review. Br J Gen Pract. 2002;52:934. [pmid: 12434964]. [pmcid: 1314447].
37 Montani S, Bellazzi R, Quaglini S, d'Annunzio G. Meta-analysis of the effect of the use of computer-based systems on the metabolic control of patients with diabetes mellitus. Diabetes Technol Ther. 2001;3:347-356. [pmid: 11762513].
38 Norris SL, Engelgau MM, Narayan KM. Effectiveness of self-management training in type 2 diabetes: a systematic review of randomized controlled trials. Diabetes Care. 2001;24:561-587. [pmid: 11289485].
39 Norris SL, Lau J, Smith SJ, Schmid CH, Engelgau MM. Self-management education for adults with type 2 diabetes: a meta-analysis of the effect on glycemic control. Diabetes Care. 2002;25:1159-1171. [pmid: 12087014].
40 Norris SL, Nichols PJ, Caspersen CJ, et al. The effectiveness of disease and case management for people with diabetes. A systematic review. Am J Prev Med. 2002;22:15-38. [pmid: 11985933].
41 Norris SL, Nichols PJ, Caspersen CJ. Increasing diabetes self-management education in comunity settings. A systematic review. Am J Prev Med. 2002;22:39-66. [pmid: 11985934].
42 Oxman AD, Thomson MA, Davis DA, Haynes RB. No magic bullets: a systematic review of 102 trials of interventions to improve professional practice. CMAJ. 1995;153:1423-1431. [pmid: 7585368]. [pmcid: 1487455].
43 Renders CM, Valk GD, Griffin SJ, Wagner EH, Eijk Van JT, Assendelft WJ. Interventions to improve the management of diabetes in primary care, outpatient, and community settings: a systematic review. Diabetes Care. 2001;24:1821-1833. [pmid: 11574449].
44 Sarkisian. A systematic review of diabetes self-care interventions for older, African American, or Latino adults. Diabetes Educ. 2003;29:467. [pmid: 12861963].
45 Valk GD, Kriegsman DM, Assendelft WJ. Patient education for preventing diabetic foot ulceration. A systematic review. Endocrinol Metab Clin North Am. 2002;31:633-658. [pmid: 12227125].
46 McDonald HP, Garg AX, Haynes RB. Interventions to enhance patient adherence to medication prescriptions: scientific review. JAMA. 2002;288:2868-2879. [pmid: 12472329].
47 Bennett JW, Glasziou PP. Computerised reminders and feedback in medication management: a systematic review of randomised controlled trials. Med J Aust. 2003;178:217-222. [pmid: 12603185].
48 Pham B, Platt R, McAuley L, Klassen TP, Moher D. Is there a “best” way to detect and minimize publication bias? An empirical evaluation. Eval Health Prof. 2001;24:109-125. [pmid: 11523382].
49 Macaskill P, Walter SD, Irwig L. A comparison of methods to detect publication bias in meta-analysis. Stat Med. 2001;20:641-654. [pmid: 11223905].
50 Sutton AJ, Song F, Gilbody SM, Abrams KR. Modelling publication bias in meta-analysis: a review. Stat Methods Med Res. 2000;9:421-445. [pmid: 11191259].
51 McAuley L, Pham B, Tugwell P, Moher D. Does the inclusion of grey literature influence estimates of intervention effectiveness reported in meta-analyses?. Lancet. 2000;356:1228-1231. [pmid: 11072941].
52 Burdett S, Stewart LA, Tierney JF. Publication bias and meta-analyses: a practical example. Int J Technol Assess Health Care. 2003;19:129-134. [pmid: 12701945].
53 Cook DJ, Guyatt GH, Ryan G, et al. Should unpublished data be included in meta-analyses? Current convictions and controversies. JAMA. 1993;269:2749-2753. [pmid: 8492400].
54 Jamtvedt G, Young JM, Kristoffersen DT, Thomson O'Brien MA, Oxman AD. Audit and feedback: effects on professional practice and health care outcomes (Cochrane Review). In: The Cochrane Library, 4 Number, 2003. Chichester, UK: John Wiley & Sons, Ltd.
55 Thomson O'Brien MA, Freemantle N, Oxman AD, Wolf F, Davis DA, Herrin J. Continuing education meetings and workshops: effects on professional practice and health care outcomes. In: The Cochrane Library, 1 Number, 2003. Oxford: Update Software.
56 Thomson O'Brien MA, Oxman AD, Davis DA, Haynes RB, Freemantle N, Harvey EL. Educational outreach visits: effects on professional practice and health care outcomes (Cochrane Review). In: In: The Cochrane Library, Issue 4, 4 Number, 2003. Chichester, UK: John Wiley & Sons, Ltd.
57 Centers for Medicare & Medicaid Services (CMS). Peer Review Organization Manual: Part 16 - Health Care Quality Improvement Program. Available at: http://www.cms.hhs.gov/manuals/19_pro/pr16.asp. Accessed November 20, 2003.
58 Chalmers TC, Frank CS, Reitman D. Minimizing the three stages of publication bias. JAMA. 1990;263:1392-1395. [pmid: 2406473].
59 Dickersin K. The existence of publication bias and risk factors for its occurrence. JAMA. 1990;263:1385-1389. [pmid: 2406472].
60 Klassen TP, Wiebe N, Russell K, et al. Abstracts of randomized controlled trials presented at the society for pediatric research meeting: an example of publication bias. Arch Pediatr Adolesc Med. 2002;156:474-479. [pmid: 11980553].
61 Krzyzanowska MK, Pintilie M, Tannock IF. Factors associated with failure to publish large randomized trials presented at an oncology meeting. JAMA. 2003;290:495-501. [pmid: 12876092].
62 Stern JM, Simes RJ. Publication bias: evidence of delayed publication in a cohort study of clinical research projects. BMJ. 1997;315:640-645. [pmid: 9310565]. [pmcid: 2127436].
63 Sutton AJ, Duval SJ, Tweedie RL, Abrams KR, Jones DR. Empirical assessment of effect of publication bias on meta-analyses. BMJ. 2000;320:1574-1577. [pmid: 10845965]. [pmcid: 27401].
64 Eccles M, Grimshaw J, Campbell M, Ramsay C. Research designs for studies evaluating the effectiveness of change and improvement strategies. Qual Saf Health Care. 2003;12:47-52. [pmid: 12571345]. [pmcid: 1743658].
65 Kerry SM, Bland JM. Sample size in cluster randomisation. BMJ. 1998;316:549. [pmid: 9501723].
66 Kerry SM, Bland JM. Statistics notes: The intracluster correlation coefficient in cluster randomisation. BMJ. 1998;316:1455-1460. [pmid: 9572764]. [pmcid: 1113123].
67 Campbell MK, Mollison J, Grimshaw JM. Cluster trials in implementation research: estimation of intracluster correlation coefficients and sample size. Stat Med. 2001;20:391-399. [pmid: 11180309].
68 Torgerson DJ. Contamination in trials: is cluster randomisation the answer?. BMJ. 2001;322:355-357. [pmid: 11159665]. [pmcid: 1119583].
69 Donner A, Piaggio G, Villar J. Meta-analyses of cluster randomization trials. Power considerations. Eval Health Prof. 2003;26:340-351. [pmid: 12971203].
70 Donner A, Klar N. Issues in the meta-analysis of cluster randomized trials. Stat Med. 2002;21:2971-2980. [pmid: 12325113].
71 Donner A, Piaggio G, Villar J. Statistical methods for the meta-analysis of cluster randomization trials. Stat Methods Med Res. 2001;10:325-338. [pmid: 11697225].
72 Localio AR, Berlin JA, Ten Have TR, Kimmel SE. Adjustments for center in multicenter studies: an overview. Ann Intern Med. 2001;135:112-123. [pmid: 11453711].
73 Stone EG, Morton SC, Hulscher ME, et al. Interventions that increase use of adult immunization and cancer screening services: a meta-analysis. Ann Intern Med. 2002;136:641-651. [pmid: 11992299].
74 Thomson O'Brien MA, Oxman AD, Haynes RB, Davis DA, Freemantle N, Harvey EL. Local opinion leaders: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2000:CD000125.
75 Berner ES, Baker CS, Funkhouser E, et al. Do local opinion leaders augment hospital quality improvement efforts? A randomized trial to promote adherence to unstable angina guidelines. Med Care. 2003;41:420-431. [pmid: 12618645].
76 Gross PA, Greenfield S, Cretin S, et al. Optimal methods for guideline implementation: conclusions from Leeds Castle meeting. Med Care. 2001;39:II85-92. [pmid: 11583124].
77 Slotnick HB, Shershneva MB. Use of theory to interpret elements of change. J Contin Educ Health Prof. 2002;22:197-204. [pmid: 12613054].
78 Campbell M, Fitzpatrick R, Haines A, et al. Framework for design and evaluation of complex interventions to improve health. BMJ. 2000;321:694-696. [pmid: 10987780]. [pmcid: 1118564].
79 Hulscher ME, Laurant MG, Grol RP. Process evaluation on quality improvement interventions. Qual Saf Health Care. 2003;12:40-46. [pmid: 12571344]. [pmcid: 1743654].
80 Hulscher ME, van Drenth BB, Mokkink HG, van der Wouden JC, Grol RP. Barriers to preventive care in general practice: the role of organizational and attitudinal factors. Br J Gen Pract. 1997;47:711-714. [pmid: 9519516]. [pmcid: 1409944].
81 Glasgow RE, Hampson SE, Strycker LA, Ruggiero L. Personal-model beliefs and social-environmental barriers related to diabetes self-management. Diabetes Care. 1997;20:556-561. [pmid: 9096980].
82 Gaede P, Vedel P, Larsen N, Jensen GV, Parving HH, Pedersen O. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. 2003;348:383-393. [pmid: 12556541].
83 Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289:2560-2572. [pmid: 12748199].
84 Executive Summary of The Third Report of The National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, And Treatment of High Blood Cholesterol In Adults (Adult Treatment Panel III). JAMA. 2001;285:2486–2497.
85 Grimshaw JM, Thomas RE, MacLennan G, et al. Effectiveness and efficiency of guideline dissemination and implementation strategies. Health Technol Assess. 2004:in press.
86 Hahn GJ, Meeker WQ. Statistical Intervals: A Guide for Practitioners. New York: John Wiley & Sons, Inc.; 1991.
87 Frijling BD, Lobo CM, Hulscher ME, et al. Multifaceted support to improve clinical decision making in diabetes care: a randomized controlled trial in general practice. Diabet Med. 2002;19:836-842. [pmid: 12358871].
88 Kinmonth AL, Woodcock A, Griffin S, Spiegal N, Campbell MJ. Randomised controlled trial of patient centred care of diabetes in general practice: impact on current wellbeing and future disease risk. The Diabetes Care From Diagnosis Research Team. BMJ. 1998;317:1202-1208. [pmid: 9794859].
89 Meigs JB, Cagliero E, Dubey A, et al. A controlled trial of web-based diabetes disease management: the MGH diabetes primary care improvement project. Diabetes Care. 2003;26:750-757. [pmid: 12610033].
90 Pocock SJ, Assmann SE, Enos LE, Kasten LE. Subgroup analysis, covariate adjustment and baseline comparisons in clinical trial reporting: current practice and problems. Stat Med. 2002;21:2917-2930. [pmid: 12325108].
91 Senn S. Testing for baseline balance in clinical trials. Stat Med. 1994;13:1715-1726. [pmid: 7997705].
92 Senn S. Baseline comparisons in randomized clinical trials. Stat Med. 1991;10:1157-1159. [pmid: 1876802].
93 Altman DG, Dore CJ. Randomisation and baseline comparisons in clinical trials. Lancet. 1990;335:149-153. [pmid: 1967441].
94 Senn SJ. Covariate imbalance and random allocation in clinical trials. Stat Med. 1989;8:467-475. [pmid: 2727470].
95 Vickers AJ, Altman DG. Statistics notes: Analysing controlled trials with baseline and follow up measurements. BMJ. 2001;323:1123-1124. [pmid: 11701584]. [pmcid: 1121605].
96 Benjamin EM, Schneider MS, Hinchey KT. Implementing practice guidelines for diabetes care using problem-based learning. A prospective controlled trial using firm systems. Diabetes Care. 1999;22:1672-1678. [pmid: 10526733].
97 Jaber LA, Halapy H, Fernet M, Tummalapalli S, Diwakaran H. Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother. 1996;30:238-243. [pmid: 8833557].
98 Oh JA, Kim HS, Yoon KH, Choi ES. A telephone-delivered intervention to improve glycemic control in type 2 diabetic patients. Yonsei Med J. 2003;44:1-8. [pmid: 12619168].
99 Vrijhoef HJ, Diederiks JP, Spreeuwenberg C, Wolffenbuttel BH, van Wilderen LJ. The nurse specialist as main care-provider for patients with type 2 diabetes in a primary care setting: effects on patient outcomes. Int J Nurs Stud. 2002;39:441-451. [pmid: 11909620].
100 McKee M, Britton A, Black N, McPherson K, Sanderson C, Bain C. Methods in health services research. Interpreting the evidence: choosing between randomised and non-randomised studies. BMJ. 1999;319:312-315. [pmid: 10426754].
101 Benson K, Hartz AJ. A comparison of observational studies and randomized, controlled trials. N Engl J Med. 2000;342:1878-1886. [pmid: 10861324].
102 Concato J, Shah N, Horwitz RI. Randomized, controlled trials, observational studies, and the hierarchy of research designs. N Engl J Med. 2000;342:1887-1892. [pmid: 10861325]. [pmcid: 1557642].
103 Grimshaw JM, Shirran L, Thomas R, et al. Changing provider behavior: an overview of systematic reviews of interventions. Med Care. 2001;39:II2-45. [pmid: 11583120].
104 Clifford RM, Batty KT, Davis TME, et al. A randomised controlled trial of a pharmaceutical care programme in high-risk diabetic patients in an outpatient clinic. International Journal of Pharmacy Practice. 2002;Vol 10:85-90.
105 Deeb LC, Pettijohn FP, Shirah JK, Freeman G. Interventions among primary-care practitioners to improve care for preventable complications of diabetes. Diabetes Care. 1988;11:275-280. [pmid: 3416683].
106 Franz MJ, Monk A, Barry B, et al. Effectiveness of medical nutrition therapy provided by dietitians in the management of non-insulin-dependent diabetes mellitus: a randomized, controlled clinical trial. J Am Diet Assoc. 1995;95:1009-1017. [pmid: 7657902].
107 Groeneveld Y, Petri H, Hermans J, Springer M. An assessment of structured care assistance in the management of patients with type 2 diabetes in general practice. Scandinavian Journal of Primary Health Care. 2001;Vol 19:30.
108 Hartmann, et al. Effects of peer-review groups on physicians' practice. Eur J Gen Pract. 1995;1:107.
109 Legorreta AP, Peters AL, Ossorio RC, Lopez RJ, Jatulis D, Davidson MB. Effect of a comprehensive nurse-managed diabetes program: an HMO prospective study. Am J Manag Care. 1996;2:1024-1030.
110 Lobach DF, Hammond WE. Computerized decision support based on a clinical practice guideline improves compliance with care standards. Am J Med. 1997;102:89-98. [pmid: 9209205].
111 Palmer RH, Louis TA, Hsu LN, et al. A randomized controlled trial of quality assurance in sixteen ambulatory care practices. Med Care. 1985;23:751-770. [pmid: 3892184].
112 Pouwer F, Snoek FJ, van der Ploeg HM, Ader HJ, Heine RJ, IN. Monitoring of psychological well-being in outpatients with diabetes: effects on mood, HbA(1c), and the patient's evaluation of the quality of diabetes care: a randomized controlled trial. Diabetes Care. 2001;24:1929–1935.
113 Renders CM, Valk GD, Franse LV, et al. Long-term effectiveness of a quality improvement program for patients with type 2 diabetes in general practice. Diabetes Care. 2001;24:1365-1370. [pmid: 11473071].
114 Walker EA, Engel SS, Zybert PA, IN. Dissemination of diabetes care guidelines: lessons learned from community health centers. Diabetes Educator. 2001;27:101–110.
115 Ward A, Kamien M, Mansfield F, Fatovich B. Educational feedback in the management of type 2 diabetes in general practice. Education for General Practice. 1996;7:142-150.
116 Cagliero E, Levina EV, Nathan DM. Immediate feedback of HbA1c levels improves glycemic control in type 1 and insulin-treated type 2 diabetic patients. Diabetes Care. 1999;22:1785-1789. [pmid: 10546008].
117 Levetan CS, Dawn KR, Robbins DC, Ratner RE. Impact of computer-generated personalized goals on HbA(1c). Diabetes Care. 2002;25:2-8. [pmid: 11772893].
118 Lim FS, Toh MP, Emmanuel SC, Chan SP, Lim G. A preliminary evaluation of a disease management programme for patients with diabetes mellitus and hypertension in a primary healthcare setting. Ann Acad Med Singapore. 2002;31:431-439. [pmid: 12161877].
119 Ovhed I, Johansson E, Odeberg H, Rastam L. A comparison of two different team models for treatment of diabetes mellitus in primary care. Scand J Caring Sci. 2000;14:253-258. [pmid: 12035216].
120 Smith SA, Murphy ME, Huschka TR, et al. Impact of a diabetes electronic management system on the care of patients seen in a subspecialty diabetes clinic. Diabetes Care. 1998;21:972-976. [pmid: 9614616].
121 Stroebel RJ, Scheitel SM, Fitz JS, et al. A randomized trial of three diabetes registry implementation strategies in a community internal medicine practice. Jt Comm J Qual Improv. 2002;28:441-450. [pmid: 12174408].
122 Vaughan NJ, Potts A. Implementation and evaluation of a decision support system for type II diabetes. Comput Methods Programs Biomed. 1996;50:247-251. [pmid: 8894384].
123 Blonde L, Guthrie R, Testa M, et al. Diabetes management by a team of diabetes nurse educators, endocrinologists and primary care physicians in a managed care setting [abstract]. Book/Association for Health Services Research.16:318–319.
124 Thompson. A team approach to diabetic foot care: the Manchester experience. Foot. 1991;1:75-82.
125 Sullivan FM. The costs and benefits of introducing a nurse-run diabetic review service in general practice. Practical Diabetes. 1991;8:47-50.
126 Ahring KK, Ahring JP, Joyce C, Farid NR. Telephone modem access improves diabetes control in those with insulin-requiring diabetes. Diabetes Care. 1992;15:971-975. [pmid: 1505329].
127 Hoskins PL, Fowler PM, Constantino M, Forrest J, Yue DK, Turtle JR. Sharing the care of diabetic patients between hospital and general practitioners: does it work?. Diabet Med. 1993;10:81-86. [pmid: 8435994].
128 Hurwitz B, Goodman C, Yudkin J. Prompting the clinical care of non-insulin dependent (type II) diabetic patients in an inner city area: one model of community care. BMJ. 1993;306:624-630. [pmid: 8461815]. [pmcid: 1676949].
129 Litzelman DK, Slemenda CW, Langefeld CD, et al. Reduction of lower extremity clinical abnormalities in patients with non-insulin-dependent diabetes mellitus. A randomized, controlled trial. Ann Intern Med. 1993;119:36-41. [pmid: 8498761].
130 Integrated care for diabetes: clinical, psychosocial, and economic evaluation. Diabetes Integrated Care Evaluation Team. BMJ. 1994;308:1208–1212.
131 Coffey E, Moscovice I, Finch M, Christianson JB, Lurie N. Capitated Medicaid and the process of care of elderly hypertensives and diabetics: results from a randomized trial. Am J Med. 1995;98:531-536. [pmid: 7778569].
132 Feder G, Griffiths C, Highton C, Eldridge S, Spence M, Southgate L. Do clinical guidelines introduced with practice based education improve care of asthmatic and diabetic patients? A randomised controlled trial in general practices in east London. BMJ. 1995;311:1473-1478. [pmid: 8520339]. [pmcid: 2543702].
133 Weinberger M, Kirkman MS, Samsa GP, et al. A nurse-coordinated intervention for primary care patients with non-insulin-dependent diabetes mellitus: impact on glycemic control and health-related quality of life. J Gen Intern Med. 1995;10:59-66. [pmid: 7730940].
134 Albisser AM, Harris RI, Sakkal S, Parson ID, Chao SC. Diabetes intervention in the information age. Med Inform (Lond). 1996;21:297-316. [pmid: 9179834].
135 Ginsberg BH. Preliminary results of a disease state management program or diabetes. J Clin Outcomes Manage. 1996;3:45.
136 Glasgow RE, Toobert DJ, Hampson SE. Effects of a brief office-based intervention to facilitate diabetes dietary self-management. Diabetes Care. 1996;19:835-842. [pmid: 8842601].
137 O'Connor PJ, Rush WA, Peterson J, et al. Continuous quality improvement can improve glycemic control for HMO patients with diabetes. Arch Fam Med. 1996;5:502-506. [pmid: 8930220].
138 de Sonnaville JJ, Bouma M, Colly LP, Deville W, Wijkel D, Heine RJ. Sustained good glycaemic control in NIDDM patients by implementation of structured care in general practice: 2-year follow-up study. Diabetologia. 1997;40:1334-1340. [pmid: 9389427].
139 Ronnemaa T, Hamalainen H, Toikka T, Liukkonen I. Evaluation of the impact of podiatrist care in the primary prevention of foot problems in diabetic subjects. Diabetes Care. 1997;20:1833-1837. [pmid: 9405902].
140 Aubert RE, Herman WH, Waters J, et al. Nurse case management to improve glycemic control in diabetic patients in a health maintenance organization. A randomized, controlled trial. Ann Intern Med. 1998;129:605-612. [pmid: 9786807].
141 Branger PJ, van't Hooft A, van der Wouden JC, Moorman PW, van Bemmel JH. Shared care for diabetes: supporting communication between primary and secondary care. Int J Med Inf. 1999;53:133-142.
142 Dargis V, Pantelejeva O, Jonushaite A, Vileikyte L, Boulton AJ. Benefits of a multidisciplinary approach in the management of recurrent diabetic foot ulceration in Lithuania: a prospective study. Diabetes Care. 1999;22:1428-1431. [pmid: 10480504].
143 Sadur CN, Moline N, Costa M, et al. Diabetes management in a health maintenance organization. Efficacy of care management using cluster visits. Diabetes Care. 1999;22:2011-2017. [pmid: 10587835].
144 Thompson DM, Kozak SE, Sheps S. Insulin adjustment by a diabetes nurse educator improves glucose control in insulin-requiring diabetic patients: a randomized trial. CMAJ. 1999;161:959-962. [pmid: 10551191]. [pmcid: 1230704].
145 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16:210-227. [pmid: 10815366].
146 Piette JD, Weinberger M, McPhee SJ, Mah CA, Kraemer FB, Crapo LM. Do automated calls with nurse follow-up improve self-care and glycemic control among vulnerable patients with diabetes?. Am J Med. 2000;108:20-27. [pmid: 11059437].
147 Kiefe CI, Allison JJ, Williams OD, Person SD, Weaver MT, Weissman NW. Improving quality improvement using achievable benchmarks for physician feedback: a randomized controlled trial. JAMA. 2001;285:2871-2879. [pmid: 11401608].
148 McDermott RA, Schmidt BA, Sinha A, Mills P. Improving diabetes care in the primary healthcare setting: a randomised cluster trial in remote Indigenous communities. Med J Aust. 2001;174:497-502. [pmid: 11419768].
149 Olivarius NF, Beck-Nielsen H, Andreasen AH, Horder M, Pedersen PA. Randomised controlled trial of structured personal care of type 2 diabetes mellitus. BMJ. 2001;323:970-975. [pmid: 11679387]. [pmcid: 59690].
150 Piette JD, Weinberger M, Kraemer FB, McPhee SJ. Impact of automated calls with nurse follow-up on diabetes treatment outcomes in a Department of Veterans Affairs Health Care System: a randomized controlled trial. Diabetes Care. 2001;24:202-208. [pmid: 11213866].
151 Reed RL, Revel AO, Carter A, Saadi HF, Dunn EV. A clinical trial of chronic care diabetic clinics in general practice in the United Arab Emirates: a preliminary analysis. Arch Physiol Biochem. 2001;109:272-280. [pmid: 11880932].
152 Wagner EH, Grothaus LC, Sandhu N, et al. Chronic care clinics for diabetes in primary care: a system-wide randomized trial. Diabetes Care. 2001;24:695-700. [pmid: 11315833].
153 Hirsch IB, Goldberg HI, Ellsworth A, et al. A multifaceted intervention in support of diabetes treatment guidelines: a controlled trial. Diabetes Res Clin Pract. 2002;58:27-36. [pmid: 12161054].
154 Clancy DE, Brown SB, Magruder KM, Huang P. Group visits in medically and economically disadvantaged patients with type 2 diabetes and their relationships to clinical outcomes. Top Health Inf Manage. 2003;24:8-14. [pmid: 12674390].
155 Kogan JR, Reynolds EE, Shea JA. Effectiveness of report cards based on chart audits of residents' adherence to practice guidelines on practice performance: a randomized controlled trial. Teach Learn Med. 2003;15:25-30. [pmid: 12632705].
156 Hayes TM, Harries J. Randomised controlled trial of routine hospital clinic care versus routine general practice care for type II diabetics. Br Med J (Clin Res Ed). 1984;289:728-730.
157 Mazzuca SA, Moorman NH, Wheeler ML, et al. The diabetes education study: a controlled trial of the effects of diabetes patient education. Diabetes Care. 1986;9:1-10. [pmid: 3948638].
158 Boucher BJ, Claff HR, Edmonson M, et al. A pilot Diabetic Support Service based on family practice attenders: comparison with diabetic clinics in east London. Diabet Med. 1987;4:480-484. [pmid: 2959442].
159 Cochrane Effective Practice and Organisation of Care Group. EPOC Data Collection Checklist. Available at: http://www.epoc.uottawa.ca/register.htm. Accessed November 17, 2003.
160 Whiting-O'Keefe QE, Henke C, Simborg DW. Choosing the correct unit of analysis in Medical Care experiments. Med Care. 1984;22:1101-1114. [pmid: 6513619].
161 Hendricks LE, Hendricks RT. The effect of diabetes self-management education with frequent follow-up on the health outcomes of African American men. Diabetes Educ. 2000;26:995-1002. [pmid: 11912812].
162 Boehm S, Schlenk EA, Raleigh E, Ronis D. Behavioral analysis and behavioral strategies to improve self-management of type II diabetes. Clin Nurs Res. 1993;2:327-344. [pmid: 8401245].
163 Glasgow RE, Toobert DJ, Hampson SE, Brown JE, Lewinsohn PM, Donnelly J. Improving self-care among older patients with type II diabetes: the “Sixty Something...” Study. Patient Educ Couns. 1992;19:61-74. [pmid: 1298950].
164 Wing RR, Epstein LH, Nowalk MP, Scott N, Koeske R, Hagg S. Does self-monitoring of blood glucose levels improve dietary compliance for obese patients with type II diabetes?. Am J Med. 1986;81:830-836. [pmid: 3535493].
165 Freemantle N, Harvey EL, Wolf F, Grimshaw JM, Grilli R, Bero LA. Printed educational materials: effects on professional practice and health care outcomes (Cochrane Review). In: Cochrane Database Syst Rev, 4 Number, 2003. Chichester, UK: John Wiley & Sons, Ltd.
166 van der Meijden MJ, Tange HJ, Troost J, Hasman A. Determinants of Success of Inpatient Clinical Information Systems: A Literature Review. J Am Med Inform Assoc. 2003;10:235-243. [pmid: 12626373]. [pmcid: 342046].
167 McAlister FA, Lawson FM, Teo KK, Armstrong PW. A systematic review of randomized trials of disease management programs in heart failure. Am J Med. 2001;110:378-384. [pmid: 11286953].
168 Thomas RE, Ramsay CR, McAuley L, Grimshaw JM. Unit of analysis errors should be clarified in meta-analyses. BMJ. 2003;326:397. [pmid: 12586684].
169 Kaushal R, Shojania KG, Bates DW. Effects of computerized physician order entry and clinical decision support systems on medication safety: a systematic review. Arch Intern Med. 2003;163:1409-1416. [pmid: 12824090].
170 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325(7370):941. [pmid: 12399345]. [pmcid: 130060].
171 Eccles M, Hawthorne G, Whitty P, et al. A randomised controlled trial of a patient based Diabetes Recall and Management System: the DREAM trial: a study protocol. BMC Health Serv Res. 2002;2:5. [pmid: 11914161]. [pmcid: 101376].
172 Massaro TA. Introducing physician order entry at a major academic medical center: II. Impact on medical education. Acad Med. 1993;68:25-30. [pmid: 8447888].
173 Massaro TA. Introducing physician order entry at a major academic medical center: I. Impact on organizational culture and behavior. Acad Med. 1993;68:20-25. [pmid: 8447887].
174 Chin T. Doctors pull plug on paperless system: California's Cedars-Sinai turns off its computerized physician order entry system after physicians revolt, demonstrating that implementing new technology is easier said than done. American Medical news. Feb. 17, 2003: Available at: http://www.ama-assn.org/amednews/2003/2002/2017/bil20217.htm.
175 Ash JS, Gorman PN, Seshadri V, Hersh WR. Computerized physician order entry in U.S. hospitals: results of a 2002 survey. J Am Med Inform Assoc. 2003.
176 Rith-Najarian S, Branchaud C, Beaulieu O, Gohdes D, Simonson G, Mazze R. Reducing lower-extremity amputations due to diabetes. Application of the staged diabetes management approach in a primary care setting. J Fam Pract. 1998;47:127-132. [pmid: 9722800].
177 Solberg LI. Guideline implementation: what the literature doesn't tell us. Jt Comm J Qual Improv. 2000;26:525-537. [pmid: 10983293].
178 Grimshaw J, Campbell M, Eccles M, Steen N. Experimental and quasi-experimental designs for evaluating guideline implementation strategies. Fam Pract. 2000;17(Suppl 1):S11-16. [pmid: 10735262].
179 Mason J, Freemantle N, Nazareth I, Eccles M, Haines A, Drummond M. When is it cost-effective to change the behavior of health professionals?. JAMA. 2001;286:2988-2992. [pmid: 11743840].