# Summary

Diabetes affects more than 17 million people in the United States alone. Taking into account undiagnosed cases and cases of impaired glucose tolerance, one in seven Americans either has diabetes or is at high risk for developing it. Despite a high-quality evidence base to aid providers in treating diabetes and screening for its complications, the quality of diabetes care remains less than optimal, with many patients not receiving established processes of care (such as eye and foot screening), or achieving optimal outcomes (such as controlled glycosylated hemoglobin levels).

To bring data to bear on the quality improvement opportunities cited by the Institute of Medicine (IOM) in its 2003 report, Priority Areas for National Action: Transforming Health Care Quality, the Agency for Healthcare Research and Quality (AHRQ) engaged the Stanford-UCSF Evidence-based Practice Center (EPC) to analyze the scientific literature on quality improvement strategies for some of the 20 disease and practice priorities named in the IOM Report. The resulting investigations focus on translating research into practice—identifying those activities that increase the rate at which practices known to be effective are applied to patient care in real world settings. In other words, the EPC research effort aims to help narrow the “quality gap” that is in large part responsible for suboptimal health care practices and outcomes. In addition to furthering the IOM's quality agenda, this analysis also has been prepared in support of the National Healthcare Quality Report (NHQR) (also see the National Healthcare Disparities Report).

In this, the second volume of the Closing the Quality Gap series, the authors focused on quality improvement in the management of patients with diabetes mellitus (Type 2 diabetes), which accounts for more than 90% of diabetes cases in the U.S. Quality improvement targets included measures of disease control (e.g., serum HbA_1c_, blood pressure) and provider adherence (e.g., serial monitoring of serum HbA_1c_, control of hypertension, and management of other cardiovascular risk factors, as well as monitoring for nephropathy, neuropathy, and retinopathy).

The carefully designed methodology used to review the vast amount of existing quality literature on particular diseases is the result of collaborative efforts of the editorial team, in consultation with several of the undisputed experts in the field. To ensure consistency in the review, the editors developed a taxonomy of interventions that modifies several well-established classification systems, denominating the QI strategies as follows:

1 Provider reminder systems
2 Facilitated relay of clinical data to providers
3 Audit and feedback
4 Provider education
5 Patient education
6 Promotion of self-management
7 Patient reminder systems
8 Organizational change
9 Financial, regulatory or legislative incentives

For more information regarding the origins and details of the research framework developed for the Closing the Quality Gap series, the statistical tools and analytical processes used throughout, and the target audiences expected to benefit most from the series, please refer to Volume 1—Series Overview and Methodology (AHRQ Publication No. 04-0051-1).

From an original sample of 3,601 potentially relevant articles, a total of 529 articles were reviewed at the full text level. Of the 126 articles meeting criteria for complete abstraction, approximately half dealt solely with patient education or self-management; these are likely to be reviewed in a subsequent volume of the Closing the Quality Gap series addressing these patient-focused interventions as they apply to many chronic illnesses, and therefore were excluded from this review. (Interventions involving patient education or self-management but including at least one QI strategy directed at providers or organizational change were included in the present review.) Thus, 58 articles, reporting a total of 66 comparisons, made up the final sample of studies included in the present review.

Taken as a group, interventions in the included comparisons reported a median absolute reduction in HbA_1c_ of 0.48% (inter-quartile (IQ) range: 0.20% to 1.38%) above any reductions observed in the control groups, and a median improvement in clinician adherence of 4.9% (IQ range: 3.8% to 15.0%). Studies utilizing multiple QI strategies did appear to exert stronger effects than single-intervention studies. The 32 multifaceted trials reported a median reduction in HbA_1c_ of 0.60% (IQ range: 0.30%, 1.40%), compared to no change (-0.08%, 0.16%) in trials of single interventions (p=0.01). This finding does confirm one of the authors' a priori hypotheses, but nevertheless should be interpreted with caution. Given the small number of studies involved, the lesser improvements associated with single-faceted interventions might relate to the specific strategies employed in these studies, rather than any intrinsic inferiority of the single-faceted QI interventions.

The investigators did not find any individual QI strategies to be unambiguously beneficial in diabetes care. Provider education resulted in large median effects for both glycemic control and clinician adherence, but these findings were of only borderline significance even before correction for multiple comparisons. Interventions employing disease or case management strategies resulted in significantly greater median reductions in serum HbA_1c_, compared with interventions lacking any component of disease management (p=0.009), but this result would not retain statistical significance after correction for the 10–15 comparisons in the analysis. Moreover, the impact of disease management was not significant in the regression analysis, which, in contrast to the median effects analysis, adjusted for study size and baseline differences between the intervention and control groups. All other evaluated QI strategies (including the integration of a computerized clinical information system) failed to improve serum HbA_1c_ levels or clinician adherence to an appreciable extent, when analyzed quantitatively.

Even when particular QI strategies (or combinations of strategies) were associated with improved outcomes or processes, these effects exhibited a striking association with sample size and trial design. For example, among the 38 trials reporting changes in mean HbA_1c_, those falling in the lower two quartiles of sample size reported a median absolute reduction in serum HbA_1c_ of 1.30%, whereas those falling in the upper two quartiles reported a median absolute reduction in serum HbA_1c_ of only 0.21%. A similar (though not statistically significant) relationship between sample size and study results was seen in studies of interventions targeting increased provider adherence. The reviewers also found a correlation between trial design (randomized vs. non-randomized) and the magnitude of the effect on QI targets such as provider adherence. For example, randomized trials of a variety of interventions reported a median absolute improvement in provider adherence of 4.5% (QI range: 3.5%, 5.4%) compared with 18.0% (QI range: 17.2%, 21.0%) for non-randomized trials. Taken together, these findings support the presence of a substantial publication bias, manifested by a greater propensity of smaller studies with non-randomized designs to be published when they report large improvements, rather than small or no improvement.

Also of interest was the discovery that studies reporting provider adherence exhibited a significant association with study period, with more recent trials reporting smaller improvements (regression coefficient: -0.04; 95% CI: -0.07 to -0.21, p=0.004). This finding appears related to the fact that baseline adherence reported in both intervention and control groups improved over time, presumably reflecting the general impact of passive relevant knowledge dissemination, as well as more active QI initiatives. Whatever its etiology, this secular trend likely means that demonstrating QI impacts becomes more difficult over time, at least in the realm of diabetes care.

In summary, this review (which expands upon previous work by virtue of its scope and the use of quantitative analysis of the effect of QI strategies on key outcomes) found that multifaceted interventions may be more likely to exert positive effects on glycemic control and (to a lesser extent) provider adherence than single interventions. The investigators were unable to identify any individual QI strategy as clearly more effective than any other. The review also uncovered probable publication bias, as well as a significant diminution of effect in more recent trials.