# Methods

## Types of Quality Improvement Strategies

A variety of interventions have been tested with the goal of improving the quality of care for common clinical conditions. From the literature, a conceptual framework has been developed for the classification of quality improvement strategies (See Chapters 1–3). These interventions can target organizations, providers, patient communities, or individual patients, and have been evaluated in a wide variety of formats. For each study, reviewers described key features of the intervention in free-text format and answered a series of questions designed to characterize the intervention in terms of its component QI strategies. The taxonomy of QI strategies is defined as follows:

Provider reminders—Information tied to a specific clinical encounter, provided verbally, in writing, or by computer, that is intended to prompt the clinician to recall information (e.g., to make medication adjustments or order appropriate screening tests), or to consider performing a specific process of care. The phrase “tied to a specific clinical encounter” distinguishes reminder systems from the audit and feedback strategy, where clinicians are typically presented with summaries of their performance relative to a process or outcome of care over multiple encounters.

Facilitated relay of clinical data to providers—Clinical information collected directly from patients is relayed to the provider in situations where the data are not generally collected during a patient visit, or when collected using a means other than the existing local medical record system (e.g., transmission of a patient's home glucose level). The investigators expected there to be some overlap with the provider reminder systems strategy, but kept them separate at the abstraction stage. This was done to allow for the possibility that the data could be subsequently analyzed with and without collapsing the strategies.

Audit and feedback—Any summary of a health care provider's clinical performance or an institution's clinical performance that is reported, either publicly or confidentially, to or about the clinician or institution (e.g., the percentage of a provider's patients who have achieved or have not achieved some clinical target). The practice of benchmarking refers to the distribution of performance data from institutions or providers regarded as leaders in the field. It is considered a type of audit and feedback, so long as local data is provided in addition to the benchmark figures.

Provider education—Any intervention that includes one of the following three substrategies: educational workshops, meetings (e.g., traditional Continuing Medical Education [CME]), and lectures (live or computer-based); educational outreach visits (the use of a trained person who meets with providers in their practice settings to disseminate information intended to change the provider's practice); or the distribution of educational materials (published or printed recommendations for clinical care, including clinical practice guidelines, audio-visual materials and electronic publications).

Patient education—Live appearance patient education, for individuals or members of a patient group or community, or via the distribution of printed or audio-visual educational materials. Only those approaches that include patient education as part of a multifaceted strategy were evaluated. Those in which patient education was the sole approach were excluded. One of the upcoming volumes in the Closing the Quality Gap series may be used to review the topic of patient education with regard to its effect on a variety of chronic diseases, including diabetes.

Promotion of self-management—The distribution of materials (e.g., devices for glucose self-monitoring) or access to a resource that enhances the patients' ability to manage their condition, the communication of clinical test data back to the patient, or followup phone calls from the provider to the patient with recommended adjustments to care. The authors expected some overlap with the patient education and patient reminders strategies, but elected to separate the strategies at the abstraction stage. This was done to allow for the possibility that the data could be analyzed subsequently, with and without collapsing the strategies.

Patient reminders—Any effort directed toward patients that encourages them to keep appointments or adhere to other aspects of self-care.

Organizational change—Changes in the structure or delivery of care designed to improve the efficiency or breadth and depth of clinical care. These include the use of disease management or case management tactics (coordination of assessment, treatment, and arrangement for referrals by a person or multidisciplinary team in collaboration with or supplementary to the primary care provider); other personnel or team changes; the use of telemedicine (communication and case discussion between distant health care professionals); Total Quality Management (TQM) or Continuous Quality Improvement (CQI) approaches (quality problem cycles of measurement, intervention design, implementation, and re-measurement); and changes to medical records systems or hospital information systems. Three substrategies (disease/case management, team/staffing changes, and medical records changes) also were extracted for analysis in studies that identified organizational change as one of their multiple strategies.

Financial, regulatory, or legislative incentives—Interventions with positive or negative financial incentives directed at providers (e.g., linked to adherence to some process of care or achievement of some target patient outcome). This strategy also included positive or negative financial incentives directed at patients, system-wide changes in reimbursement (e.g., capitation, prospective payment, or a shift from fee-for-service to salary pay structure), changes to provider licensure requirements, or changes to institutional accreditation requirements.

In addition to the aforementioned QI strategies, the authors had planned initially to abstract data on intervention features such as social influence (e.g., local opinion leaders ^74,^ ^75^ ), the involvement of top-level management, intervention designs based on a theory of behavior or organizational change, ^76^ – ^78^ and other potential “mediators” of intervention success. ^73^ Unfortunately, the identified studies rarely explored these and other potentially relevant features of intervention design. ^79^ Moreover, few studies considered organizational context ^80^ and local attitudes and beliefs, ^81^ so questions targeting these potential predictors of intervention success or failure were eliminated from the abstraction forms and from the analysis.

The one “mediator” that reviewers anticipated would be reported with sufficient frequency and detail was the use of clinical information systems, which was identified as a potential predictor of success in a prior review. ^16,^ ^43^ For each article, therefore, the involvement of a clinical information system in the design or implementation of the intervention was recorded (regardless of QI strategy type). The potential roles identified in structured form were: identification and/or group allocation of eligible patients or providers; reminders generated by existing clinical information system; and decision support at point of care. Additional potential roles include facilitated communication between providers (e.g., generation of e-mails between members of care team); and audit data gathered from clinical information systems to design QI strategy (e.g., audit and feedback, TQM, provider education, or financial incentives).

## Scope

This report focuses on quality improvement strategies that target adult patients with type 2 diabetes mellitus (DM). Type 2 diabetes accounts for 90–95% of diabetes cases in the United States. It is the sixth leading cause of death among the general U.S. population, and is the seventh leading cause of disability among adults. ^1^ Numerous trials in this patient population show that diabetes-related morbidity and mortality can be reduced with close adherence to treatment guidelines. Accordingly, quality improvement strategies have a tendency to focus on adult type 2 diabetics. The reviewers did not assess QI strategies for children with diabetes, due to the higher prevalence of type 1 DM (although cases of type 2 DM also are on the rise among children), as well as the unique challenges involved with the treatment of this patient population and their potential to limit the applicability of QI strategies tested in the adult population. Studies that focused exclusively on gestational diabetes also were excluded.

A wide range of interventions targeting patient behavior, individual provider behavior, and systemic problems has been researched and implemented to address these quality gaps. As documented previously, the treatment goals for diabetic patients are clear and well supported by research. Providers can avail themselves of a variety of safe and effective treatments to help patients reach these goals. Thus, the focus of this review is interventions that seek to change the methods by which organizations or providers deliver care, with the goal of improving individual patient outcomes. Studies that focused exclusively on patient behavioral changes were not included in this review, but will likely be addressed in a future series report on patient education and self-management as QI strategies for chronic illness.

### Inclusion and Exclusion Criteria

The general inclusion criteria were described in the chapter on Methods, in Volume 1 of this series. Briefly, included studies are required to:

- Evaluate an intervention meeting the authors' definition for quality improvement (definitions summarized below);
- Use an experimental or quasi-experimental design - including patient or cluster randomized controlled trials (RCTs), quasi-randomized controlled trials (quasi-RCTs), controlled-before after studies (CBAs), and interrupted time series (ITS) (as defined below); and
- Report at least one measure of disease control, provider adherence, or patient compliance, (as defined below and in the abstraction forms in Appendix C), specifically related to diabetes.

Many of the abstracted outcomes relate to blood pressure control and modification of important cardiovascular risk factors (e.g., smoking cessation, weight loss). When a study reported such outcomes but did not include any measures specifically related to glycemic control or the prevention of diabetic complications (e.g., retinopathy, neuropathy, nephropathy, skin ulcers), the investigators did not include it. For instance, a study of blood pressure control in diabetics would be excluded from the present review if the only outcomes reported were related to hypertension. The study would, however, be eligible for inclusion in the hypertension review (Volume 3 of this series).

Studies also were excluded when their outcomes consisted solely of provider or patient understanding, satisfaction, or self-efficacy; or solely of costs and resource use (i.e., when these outcomes were not accompanied by at least one measure of disease control, provider adherence, or patient compliance).

### Included Trial Designs

Randomized trials offer the best means of isolating the effects of a given intervention, as patients in different study groups generally differ only with respect to their exposure to the treatment (i.e., other known and unknown factors affecting relevant outcomes should be distributed equally between the groups). Patient randomized trials and cluster randomized trials have been included in the review for this reason. In the former, individual patients are assigned randomly to an intervention group or a control group. Patient randomized trials represent the gold standard for health care evaluations. For trials of QI interventions, however, the advantages of patient randomized trials must be weighed against the disadvantage of contamination. Because clinicians will care for patients in both study groups, the level of care received by the control group patients may improve over the course of the trial. This could lead to an apparent null result, despite the improvement in patient outcomes occuring as a result of the intervention. ^64^

Cluster randomized trials seek to avoid this contamination by allocating the intervention at the level of clinicians as individuals or groups (e.g., clinics as the unit of allocation). This approach overcomes the problems of contamination at the cost of a decreased effective sample size. Since patients within a given “cluster” receive their care at the same participating study clinic, outcomes for these patients cannot be regarded as completely independent. ^65^ – ^72^ The statistical correction for this violation of independence decreases the effective sample size and, as a result, the efficiency of the study. The choice of a clustered RCT versus patient RCT, therefore, depends on the magnitude of the contamination across patients that would occur under the latter design choice. ^68^ The authors' judgment regarding the appropriateness of the particular choice made in a given trial did not have a direct impact on their analysis, as the effective sample size was adjusted for cluster effects whenever the unit of analysis differed from the unit of treatment allocation.

### Terminology to Distinguish Studies, Interventions, and Comparisons

Since the reviewed articles did not present their study data in a uniform fashion, the authors adopted the following terminology to better describe the quality improvement interventions reviewed for this volume:

When a single study led to multiple publications (articles) describing different aspects of the study, (e.g., a methods article followed later by a results paper, or several results papers) each publication was identified separately and all articles emerging from the same study were reviewed together.

A single study may include several different study arms (groups of subjects), with different QI interventions provided to the subjects in each study arm. These are often reported in a single published article. For purposes of analysis, the researchers regarded each intervention that was studied in contrast to a control group as a separate comparison. For example, a single study with one control group and three different arms receiving different QI interventions (e.g., provider education and organizational change in one arm, patient reminder and organizational change in another arm, audit and feedback in a third arm), was compared with the control group, and was regarded (and listed in the Tables section) as three comparisons. When an article reported several comparisons, the reviewers performed a separate data abstraction for each comparison.

The intervention described in a particular study may be multifaceted, that is, it may involve more than one QI strategy. For example, the intervention may consist of a combination of provider education and provider reminders. A multifaceted intervention that was applied to a single study arm and judged against the control group was treated as a single comparison.

## Literature Search and Review Process

The search strategy began with a broad electronic search of the MEDLINE^®^ database from January 1966 to July 2003 (the specific search is shown in Appendix B). The reviewers augmented these results with a search of the Cochrane Collaboration's (EPOC) database, ^20,^ ^21^ (which includes the results of extensive periodic searches of the EMBASE^®^, CINAHL^®^, and MEDLINE^®^ databases), as well as hand searches of article bibliographies and specific journals. ^22^ They also performed their own MEDLINE^®^ review because of slight differences in scope (e.g., a desire to identify articles involving patient education or self-management only, even though they may be included in a subsequent volume of this series, rather than in the present review). This step was considered a means of enhancing the completeness of the EPOC database search, in an effort to be as thorough and meticulous as possible.^*^ ^17,^ ^21,^ ^23^ – ^47^

* The EPOC Web site reports a sensitivity of 92.4% for the registry's search strategy and precision of 18.5%, but the gold standard of hand searching included a fairly limited sample of journals and somewhat outdated time periods: Medical Care (1969-95), BMJ (1992-94), and full text searching from the Ovid Biomedical Core Collection all original and miscellaneous articles from Annals of Internal Medicine, BMJ, JAMA and Lancet (1995-96).

To meet the criteria for full abstraction, articles had to assess the effect of a quality improvement strategy on disease control, provider adherence, or patient adherence in adults. (Appendix C shows the structured abstraction forms used to guide these judgments.) A total of 529 articles merited full-text reviews. These involved two independent reviewers, at least one of whom was a core investigator or senior methodologist (as opposed to a trained research assistant). At the full-text level, reviewers abstracted basic information on the study design, quality improvement strategy, and variety of outcomes. (The complete full-text abstraction form also is shown in Appendix C.) All disagreements were resolved by consensus.

### Publication Bias

Publication bias refers to an overestimation of effect size, and is due to the preferential publication of positive studies. Given the absence of a single, well-established analytic method for detecting or correcting the effects of publication bias, ^48^ – ^50^ the preferred approach to preventing this source of error is a thorough search for unpublished research. ^51^ – ^53^ Unfortunately, the search for unpublished quality improvement trials is complicated by a paucity of well-defined and centralized information resources. Unlike research into topics of clinical care, (e.g., determining the best drug to use in the event of heart failure or the preferred test for pulmonary embolism), there are no relevant clinical trial registries for QI strategies or pharmaceutical companies to query for unpublished data. For disease-specific reviews, as opposed to reviews of general strategies (e.g., audit and feedback, ^54^ provider education, ^55,^ ^56^ disease management, ^17^ etc.), some conference proceedings related to the disease or specialty may exist. To that end, the conference proceedings of several prominent meetings in endocrinology and diabetes care were reviewed.

Another problem that may exacerbate the impact of publication bias on reviews of quality improvement studies involves the research often conducted by personnel interested in pragmatic, local quality improvement. The results of such studies may be less likely to be submitted for publication, while investigators involved in clinical research trials generally have a stronger incentive to publish. And though publication bias may occur at the level of journal acceptance, it is unlikely that investigators would opt not to submit their work anywhere, simply because the trial had a negative finding. By contrast, some quality improvement studies may be undertaken by personnel for whom quality assurance activities are a part of their job descriptions. The emphasis often is placed on measures of success in such instances, rather than on research dissemination. In effect, the incentive to publish may be particularly low when the evaluation result is negative.

One exception to the generalization regarding the dearth of sources for unpublished QI trials is the Health Care Quality Improvement Program (HCQIP) database, maintained by the U.S. Centers for Medicare & Medicaid Services (CMS). ^57^ This database includes descriptions of research projects conducted by Medicare Peer Review Organizations (PRO), now called Quality Improvement Organizations (QIOs). Unfortunately, the relatively unstructured format of these project narratives makes for time-intensive searches. And while recent changes to the database denied the reviewers access during the timeframe of this project, they plan to revisit the access issue for future topics in the series.

The difficulty in obtaining unpublished QI trials and vulnerability to publication bias were incentives for analyzing the studies in terms of median effect sizes. As described in greater detail in the Methods section of Volume 1, the investigators summarized their findings for a given QI type or study feature by reporting the median effect size achieved by the studies (e.g., the medianeffect on HbA_1c_ reported by studies sharing a specific QI strategy). Publication bias is more likely a factor in smaller, low quality studies. ^52,^ ^58^ – ^63^ When the results are similar to other studies, they will have little effect on the median. When the results report larger effects for a given intervention, they will not affect the median so long as their total number is small.

## Outcome Measures

Investigators targeted three broad categories of study outcomes: measures of disease control, measures of provider adherence to recommended care, and patient adherence to prescribed medications and self-care recommendations. Measures of disease control included intermediate clinical outcomes such as HbA_1c_ and blood pressure, as well as clinical endpoints such as mortality, cardiovascular events, vision loss, and amputation. Quality improvement studies generally have insufficient power to detect changes in morbidity and mortality, as such studies require large numbers of patients and lengthy observation periods. ^82^ Accordingly, the focus shifted to intermediate clinical outcomes as measures of disease control, especially serum HbA_1c_ and blood pressure. HbA_1c_ levels have a well-established connection to glycemic control over time and to the prevention of important diabetic complications. ^4^ – ^6,^ ^11^ Management of cardiovascular risk factors—especially control of hypertension—now is recognized for being as important to diabetic patient outcomes as glycemic control. ^7^ Similarly, studies that promoted provider adherence to measures shown to prevent diabetic complications also were made a priority. Serial monitoring of serum HbA_1c_, blood pressure, and cholesterol, as well as monitoring for nephropathy (with microalbuminuria), neuropathy (by foot examinations), and retinopathy (with dilated retinal examinations) are widely accepted care practices (see Appendix A).

Guidelines for the care of diabetic patients continue to evolve, and significant changes have occurred within the last half-decade alone. While recommendations for optimal glycemic control have remained stable, new data have led to recommendations for tighter blood pressure and hyperlipidemia control. ^83,^ ^84^ The NCEP-III guidelines for cholesterol management were issued in 2001, and the latest Joint National Committee on the Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (JNC-VII) recommendations for hypertension management were announced in 2003. These guidelines support an LDL-cholesterol target of < 100 mg/dl and a blood pressure target of < 130/80 mmHg, for diabetic patients. But most of the quality improvement strategy trials reviewed for this study were undertaken in years when less restrictive guidelines were in place, and therefore contain targeted goals that would be considered suboptimal by current standards. Since the focus of this review was to identify effective strategies for implementation, the investigators opted to include studies designed to improve provider adherence with the targets deemed acceptable at the time of the original study—even in those instances where they no longer were consistent with present guidelines.

Core outcomes were abstracted using a structured format, in an effort to permit quantitative analysis. For measures of disease control, the core outcome consisted of changes in serum HbA_1c_ and blood pressure. Serum lipids, creatinine, and outcomes related to retinal disease and foot ulcers also were captured, with the expectation that such outcomes were reported in too many different formats across studies to permit their inclusion in the quantitative analysis. (As mentioned previously, investigators also included clinical endpoints such as death and amputation, but expected studies to report these infrequently and to be underpowered to detect differences across study groups.) For measures of provider adherence, outcomes were captured as reported in the study, but all adherence outcomes were categorized in terms of broad categories:

- Adherence to guideline targets for frequency of glycemic control assessment (e.g., measuring HbA_1c_ at least once within a specified time period).
- Adherence to recommended screening practices for ophthalmologic complications (e.g., performance of, or referral for, dilated retinal exam).
- Adherence to recommended screening practices for renal complications (e.g., checking urine microalbumin).
- Adherence to recommended screening practices for neuropathy or foot-related complications (e.g., performance of, or referral for, foot examination).
- Adherence to treatment choices for achieving glycemic control (e.g., making specific medication choices).
- Adherence to guideline targets for managing blood pressure or cardiovascular disease.
- Adherence to recommendations for patient education or counseling regarding dietary regime, exercise, smoking, and other lifestyle factors.

For measures of provider adherence, the investigators stipulated outcomes data sourced from chart reviews, direct observations, and clinical information systems, but not from provider self-reporting. They did permit data taken from patient self-reporting, for patient adherence outcomes.

Patient outcomes were collected in a similar fashion for two broad categories: adherence to prescribed medication regimens; and for adherence to self-care practices (e.g. self-monitoring of blood glucose, recommendations for diet and exercise, and keeping appointments). In accordance with a recent systematic review of strategies designed to increase adherence to prescribed medication regimens, ^46^ studies were included only if they reported at least one treatment outcome in addition to measures of adherence.

For outcomes involving medication adherence, investigators also made an effort to record the method of measurement, relative to the following categories: laboratory confirmation (e.g., the detection of a drug or metabolite in blood or urine, including biochemical assays for smoking cessation); pharmacy data (e.g., filled or refilled prescriptions); specially designed dispensers that record medication use, home medication counts, office medication counts (e.g., patients bring in bottles with unused pills); patient self-report (via interview or survey). While the number of studies reporting medication outcomes was anticipated to be too few to permit the incorporation of these measurement categories into the analysis, the data was captured in preparation for the final volume in this series and the possibility that sufficient studies may be found to examine their impact across the various priority topics.

### Formats for Reported Outcomes

The investigators anticipated four basic formats for reporting outcomes. Results could be reported at the provider level (e.g., mean blood pressure for patients cared for by a particular physician or group of physicians), or patient level (e.g., mean HbA_1c_ for individual patients in a particular clinic). These outcomes also could be reported as a summary measure for a group (e.g., mean blood pressure), or as the percentage of patients within a certain range (e.g., percentage of patients with HbA_1c_ < 9.5%). Most studies were expected to report summary data at the patient level, as the clinical significance is more immediately evident. The full-text abstraction forms were devised to target the following measures:

- Reductions in HbA_1c_, systolic blood pressure (SBP), and diastolic blood pressure (DBP) were reported as mean and standard deviation ^†^ for each study group before and after the intervention
  † Where standard error of the mean (SEM) was reported, we calculated the standard deviation (SD) based on SEM = SD/SQRT(N), for sample size N.
- Changes in adherence to a process of care were reported as the percentage of patients in each group who received the process of care before and after the intervention; changes in patient adherence to a recommended process of self-care or a medication regimen was defined similarly as the percentage of patient adherence in each group at baseline and following the intervention.

Investigators also had planned to document disease control outcomes reported as a percentage of patients with HbA_1c_, SBP, or DBP decreases within a target range. The same was true for adherence outcomes, framed as summary measures applied to providers rather than patients (e.g., in trials where clinicians were randomized, the reviewers expected some studies would report summary scores for clinicians in each group rather than for all patients within each group). So few studies reported outcomes in this manner, however, that the researchers changed their abstraction form and analytic plan to focus on outcomes reported in the formats listed previously.

## Analysis

### The Median Reported Effect as a Summary Measure

In addition to descriptive and qualitative analyses, two more forms of analysis had been planned. The first involved the calculation of a “median effect” among outcomes within a given category (e.g., all provider adherence outcomes reported by a given study) so that studies exhibiting the same features could be compared in terms of a common metric. Following the method employed in a recent systematic review of strategies for guideline implementation, ^85^ the researchers identified in each study the adherence outcome that exhibited the median improvement attributable to the intervention. For example, if a study reported one outcome involving adherence to a guideline for checking HbA_1c_, another related to screening for retinal disease, and a third outcome for delivery of patient education, investigators calculated the net improvement attributable to the intervention for each outcome. The net improvement in adherence was calculated as (Post-intervention adherence - Pre-intervention adherence)_Study group_ - (Post-intervention adherence -Pre-intervention adherence)_Control group_. Then the median value among values for the net improvement in adherence was calculated. This median value was regarded as the primary adherence outcome for that particular study.

Outcomes were not combined for measures of disease control, so the net reduction in HbA_1c_, SBP, or DBP attributable to the intervention was reported. ^‡^ However, in analyzing the impact of a particular QI type or study feature (e.g., trial design), investigators did report a similar “median effect” across studies, such as the median reduction in HbA_1c_ reported by RCTs versus CBAs, or the median reduction in HbA_1c_ reported by all studies employing a given QI type.

‡ The net change in a disease control measure such as HbA_1c_ was calculated as (Post-intervention HbA_1c_ - Pre-intervention HbA_1c_)_Study group_ - (Post-intervention HbA_1c_ - Pre-intervention HbA_1c_)_Control group_.

Focusing on median effects rather than average effects helped to eliminate skewing in the summary measure, based on one or two outliers with particularly large or small effect sizes. The reviewers regarded this effect as particularly important, given the aforementioned difficulty in accounting for publication bias. They considered the calculation of a weighted median, with weighting based on sample size, in order to avoid studies with equal weights, irregardless of size. But weighted medians are not as straight forward as weighted means, especially when the aim is to preserve the original significance of the effect size (e.g., the relation to a reduction in HbA_1c_ or SBP in the units used for those outcomes). Therefore, instead of applying a variable weighting scheme, investigators examined the median effect sizes by different strata of study sample size (e.g., comparing the median effect among studies with sample sizes in the lowest quartile against those in the highest quartile, or those in the lower half versus the upper half.

A simple non-parametric assessment—the Mann-Whitney rank-sum test—was used when possible to ascertain differences in median effects. ^86^ Such comparisons were possible only for mutually exclusive categories (e.g., randomized versus non-randomized trials) or for all interventions with a particular QI strategy compared with all those lacking the same strategy. It was not possible, however, to compare one strategy with another because of the frequent overlap between the two groups, and the contribution of the same interventions to the two medians.

### Standardization of Direction of Effect

To avoid confusion regarding the direction of effect, investigators standardized all outcomes so that a positive change would reflect improvement. Thus, all reported changes in HbA_1c_ and blood pressure are reductions, and a positive change always can be interpreted as an improvement. For adherence outcomes, the adherence target was constructed in such a way that an increase in the outcome always corresponded to an improvement. Thus, if a study reported an outcome involving the percentage of clinicians who failed to perform some process of care, the complementary percentage of clinicians who succeeded in performing the targeted process of care was used. Similarly, if a study reported an outcome involving the delivery of an undesirable process of care (e.g., prescribing a medication regarded as harmful), the complementary percentage of clinicians who did not perform the adverse process of care was used, so that a positive change would better indicate improvement.

### Accounting for “Cluster” Effects

“Clustering” was anticipated in a substantial number of studies for which the unit of analysis and unit of allocation differ (e.g., providers or clinics randomized, but patient level outcomes analyzed). Clustering is significant in that patients within a cluster are not independent (i.e., patients at one clinic have a greater resemblance to one another than to patients at other sites, or those cared for by other providers in the trial). Unit of analysis errors do not affect point estimates for effect sizes, but they may spuriously narrow the associated confidence interval, leading to potential false-positive trial results. ^65^ – ^72^ To avoid the same inflation of precision in this analysis, investigators calculated an effective sample size for each study.^§^ From the perspective of this analysis, the degree to which investigators acknowledged or accounted for cluster effects did not affect the analysis, forepart from the fact that investigators who did consider cluster effects in the design or analysis of the trial were more likely to report data such as the number of providers randomized, rather than just the total numbers of patients in each group. They also were more likely to provide more technical details, such as values for the intra-cluster coefficient (ICC). Because so few studies reported ICC values, ^87^ – ^89^ the reviewers used values derived from published estimates. ^67^ (Appendix F shows the calculation of effective sample sizes and presents sensitivity analyses based on the range of published ICC values.)

§ Effective N = (km) / (1 + (m-1)r) where k is the number of clusters and m is the number of observations per cluster and r is the intra-cluster coefficient. When r = 0, then N = km. When r = 1, then N = k. ^65^ – ^72^

### Regression Analysis

For the more involved quantitative analyses—meta-regression analysis of included studies—investigators used a more conventional measure of effect size, defined as the difference between the means of the intervention and control arms divided by the pooled estimate of the within group standard deviation.^**^ These formal effect sizes, and the above median effect measures, were constructed in such a way that a positive result always reflected improvement (e.g., a positive reduction in average HbA_1c_ or a positive improvement in adherence).

** Effect size = ([image] - [image]) / S_p_ where [image] is the mean for the intervention group, [image] is the mean for the control group and S_p_ is the pooled within groups standard deviation, which is calculated from:

S_p_ ^2^ = ( (N_I_ - 1) S_I_ ^2^ + (N_C_ - 1) S_C_ ^2^) / (N_I_ + N_C_ - 2). N_I_ and N_C_ are the intervention and control sample sizes and S_I_ and S_C_ are the intervention and control standard deviations.

Specifically, regression models were constructed using the pre-intervention effect size (ES_Pre_) as a predictor variable. Initially, each methodologic feature or QI strategy was modeled with ES_Pre_ to evaluate its effect on the post-intervention effect size (ES_Post_). Investigators subsequently developed multivariate models, using multiple components as an individual feature's covariates, in order to independently assess the effect of an individual feature after adjustment for other components. This model assumed no important interactions between types of QI strategies, provider factors, or other potential predictors. This assumption may be overly simplistic, but it was considered reasonable in the context of this exploratory analysis.

Linear regression was carried out as Y = β_0_ + β_1_ X _1_ + β_2_ X _2_, with X_1_= ES_pre_ and the dependent variable, Y, corresponding to the outcome of interest—a measure of disease control such as HbA_1c_ or the “summary adherence” outcome described above, in which the value for each study corresponds to the adherence outcome with the median effect among the outcomes reported by the study. ES_pre_ was retained as a predictor in all analyses because of expected baseline differences between the study and control groups and their role as important covariates, even when these differences did not meet conventional thresholds for statistical significance. This point is discussed in detail in the analysis of trials reporting changes in a target measurement rather than single endpoints (Volume 1, Chapter 2: Methods).

Briefly, investigators often assume that if a study is randomized, baseline values of the outcome of interest (e.g., baseline HbA_1c_ in the control and study groups) can be handled in the manner of basic demographic and clinical features reported typically as subject characteristics in a “Table 1.” Despite the common practice of reporting p-values in a “Table 1,” assessing baseline differences is philosophically unsound. If randomization has been carried out appropriately, any observed differences have, by definition, occurred on the basis of chance. ^90^ – ^94^ More importantly, even when baseline differences do not have p-values below 0.05, such differences may nevertheless exert significant effects on the observed results. ^90^ – ^94^ If the correlation is low (less than approximately 0.3), using change score from the baseline value will add variation, so the followup score is more likely to show a significant result. Conversely, if the correlation is high (greater than approximately 0.6) using only the followup score will lose information and the change score is more likely to prove significant. ^95^

Table 1 Summary features of included studies

Setting | Study period | Study Design | QI strategies employed* | Outcomes reported^†^
| (duration) | (Number of Patients)
2 endocrinology clinics (Canada) ^1^ | --- | RCT | Self-Mx, Facil Relay | Dz: HbA1c, other
| (3 months) | (42)
2 clinics, | --- | CBA | Self-Mx, Facil relay, Org change | Dz: HbA1c, other
(unspecified US city) ^2^ | (6 months) | (117)
2 clinics | --- | CBA | Self-Mx, Facil relay, Org change | Dz: HbA1c, other
(unspecified US city) ^2^ | (6 months) | (87)
2 large clinics | --- | RCT | Patient Ed, Facil relay, Org change | Dz: other
(Jacksonville, FL) ^3^ | (1 year) | (138) | | Adhere: other
2 clinics, Baystate Medical Center | 1995-1996 | Quasi-RCT | Prvdr Ed | Dz: HbA1c
(Springfield, MA) ^4^ | (15 months) | (144, 2 firms)
6 group practices | --- | CBA | Pt Remind, Prvdr Ed, Facil relay, Org change | Dz: HbA1c
(United Kingdom) ^5^ | (2 years) | (242, 6 practices)
Individual GP offices and a public hospital outpatient clinic | 1994 | CBA | Facil relay, Org change | Dz: HbA1c
(Netherlands) ^6^ | (1 year) | (275, 32 providers)
Massachusetts General Hospital Diabetes Center | --- | RCT | Facil relay | Dz: HbA1c
(Boston, MA) ^7^ | (1 year) | (201)
Medical U. of South Carolina Adult Primary Care Center | 2001 | RCT | Patient Ed, Org change | Adhere: other
(Charleston, SC) ^8^ | (6 months) | (120)
Diabetes outpatient clinic | 1998-1999 | RCT | Org change | Dz: HbA1c
(Australia) ^9^ | (1 year) | (73)
Medicaid program | --- | RCT | Financial | Pat comp
(Hennepin County, MN) ^10^ | (1 year) | (96)
Diabetes foot clinic | 1995-1997 | CBA | Patient Ed, Org change | Dz: other
(Lithuania) ^11^ | (2 years) | (145)
28 general practices | 1989-1995 | CBA | Patient Ed, Self-Mx, Facil relay, Org change | Dz: HbA1c, BP, other
(Netherlands) ^12^ | (6 years) | (505, 28 providers)
6 primary care centers | --- | CBA | Prvdr Ed, Org change | Adhere: HTN/CAD, Foot/Eye, other
(Florida) ^13^ | (2 years) | (1029, 6 practices)
24 non-training general practices | 1993 | RCT | Prvdr Ed, Audit & Fdbck | Adhere: HbA1c, HTN/CAD, Foot/Eye, other
(United Kingdom) ^14^ | (1 year) | (24 practices)
Diabetes centers | 1992-1993 | RCT | Patient Ed, Self-Mx, Org change | Dz: HbA1c
(Minnesota, Florida, Colorado) ^15^ | (6 months) | (247)
124 general practices (The Netherlands) ^16^ | 1996-1999 | RCT | Prvdr Ed, Audit & Fdbck | Adhere: HTN/CAD, Foot/Eye, other
| (3 years) | (1431, 124 practices)
Diabetes clinic (Denmark) ^17,^ ^18^ ^†^ | 1993-2001 | RCT | Patient Ed, Org change | Dz: HbA1c, BP, other
| (9 years) | (160)
University-affiliated family practice clinic | --- | RCT | Patient Ed, Prvdr Ed | Dz: HbA1c
(unspecified US city) ^19^ | (6 months) | (67)
2 primary care clinics | --- | RCT | Patient Ed, Self-Mx, Org change | Dz: HbA1c, other
(unspecified US city) ^20^ | (3 months) | (200)
Specialized diabetic service | --- | RCT | Patient Ed, Facil relay, Org change | Dz: HbA1c, BP, other
(Netherlands) ^21^ | (1 year) | (246, 15 practices)
10 primary care practices | 1993 | CBA | Prvdr Ed, Audit & Fdbck | Adhere: HbA1c, HTN/CAD, Foot/Eye, other
(Germany) ^22^ | (8 months) | (403, 17 providers) | | Pat comp
Hospital diabetic clinic and GP offices | --- | RCT | Prvdr Ed, Org change | Dz: HbA1c
(United Kingdom) ^23^ | (5 years) | (200)
29 general practices | --- | RCT | Prvdr Remind, Audit & Fdbck | Dz: HbA1c, BP
(Norway) ^24^ | (21 months) | (1034, 17 practices) | | Adhere: HbA1c, HTN/CAD, other
U. of Washington Family Medical Center | 1998-1999 | RCT | Prvdr Ed, Audit & Fdbck, Org change | Dz: HbA1c, BP
(Seattle, WA) ^25^ | (14 months) | (109, 2 firms)
Royal Prince Alfred Hospital Diabetes Clinic | --- | RCT | Org change | Dz: HbA1c, BP, other
(Australia) ^26^ | (1 year) | (137) | | Adhere: HbA1c, HTN/CAD, other
| | | | Pat comp
Royal Prince Alfred Hospital Diabetes Clinic | --- | RCT | Self-Mx, Pt Remind, Prvdr Remind, Org change | Dz: HbA1c, BP, other
(Australia) ^26^ | (1 year) | (134) | | Adhere: HbA1c, HTN/CAD, other
| | | | Pat comp
General practices | 1988-1990 | RCT | Pt Remind, Facil relay | Dz: HbA1c, other
(Great Britain) ^27^ | (31 months) | (181)
University-affiliated outpatient clinic | --- | RCT | Patient Ed, Org change | Dz: HbA1c, other
(unspecified US city) ^28^ | (4 months) | (45)
Ambulatory Care Quality Improvement Project | 1996-1998 | RCT | Audit & Fdbck | Adhere: HbA1c, Foot/Eye
(Alabama) ^29^ | (25 months) | (1931, 70 providers)
Cedars Sinai Medical Center | 1994-1995 | RCT | Patient Ed, Prvdr Ed | Dz: HbA1c, BP, other
(Los Angeles, CA) ^30^ | (1 year) | (360, 43 practice teams)
5 outpatient practices in a university-based training program ^31^ | 1998-1999 | RCT | Audit & Fdbck | Adhere: other
| (1 year) | (497, 44 providers)
2 clinics | --- | CBA | Pt Remind, Prvdr Ed, Org change | Dz: HbA1c, other
(unspecified California city) ^32^ | (1 year) | (2 practices)
14 independent physician offices | --- | CBA | Pt Remind, Prvdr Ed, Org change | Dz: HbA1c, other
(unspecified California city) ^32^ | (1 year) | (2 practices)
Diabetes education program | 1998-1999 | RCT | Patient Ed, Self-Mx, Pt Remind, Prvdr Remind, Facil relay | Dz: HbA1c, BP, other
(unspecified US city) ^33^ | (6 months) | (150)
Choa Chu Kang polyclinic | 2000-2001 | CBA | Patient Ed, Prvdr Remind, Org change | Dz: HbA1c, BP
(Singapore) ^34^ | (7 months) | (211)
Academic general medicine practice, Regenstrief Health Center | 1989-1991 | RCT | Patient Ed, Pt Remind, Prvdr Ed, Prvdr Remind | Dz: other, Pat comp
(Indianapolis, Indiana) ^35^ | (2 years) | (396, 4 firms)
Duke Family Medicine Center | 1993-1994 | RCT | Prvdr Remind | Adhere: HbA1c, HTN/CAD, Foot/Eye, other
(North Carolina) ^36^ | (6 months) | (58 providers)
General medicine clinic, Indiana University Medical Center ^37^ | 1978-1982 | RCT | Prvdr Ed, Prvdr Remind, Audit & Fdbck | Dz: HbA1c, BP, other
| (3 years) | (260, 13 firms)
General medicine clinic, Indiana University Medical Center ^37^ | 1978-1982 | RCT | Patient Ed, Pt Remind, Prvdr Ed, Prvdr Remind, Audit & Fdbck | Dz: HbA1c, BP, other
| (3 years) | (273, 14 firms)
21 primary healthcare sites | 1999-2000 | RCT | Pt Remind, Prvdr Ed, Prvdr Remind, Audit & Fdbck, Org change | Dz: other
(Australia) ^38^ | (13 months) | (727, 21 practices) | | Adhere: HbA1c, HTN/CAD, Foot/Eye, other
Hospital-based Adult Medicine Clinic | 1998-1999 | RCT | Prvdr Ed, Prvdr Remind | Dz: HbA1c, BP, other
(unspecified US city) ^39^ | (1 year) | (598, 2 firms) | | Adhere: HbA1c, HTN/CAD, Foot/Eye, other
2 clinics | 1993-1995 | CBA | Patient Ed, Audit & Fdbck, Org change | Dz: HbA1c, other
(unspecified Midwest US city) ^40^ | (21 months) | (267, 2 practices)
Endocrinology dept. tertiary care hospital | 2000-2001 | RCT | Patient Ed, Facil relay | Dz: HbA1c, other
(South Korea) ^41^ | (3 months) | (50)
311 general practices | 1989-1995 | RCT | Patient Ed, Prvdr Ed, Prvdr Remind, Audit & Fdbck | Dz: other
(Denmark) ^42^ | (6 years) | (1263, 484 providers)
2 primary health-care centers | 1993-1994 | CBA | Org change | Adhere: HbA1c, HTN/CAD, Foot/Eye, other
(Sweden) ^43^ | (1 year) | (408, 2 practices) | | Pat Comp
16 teaching-hospital affiliated primary care practices | --- | CBA | Audit & Fdbck, Org change | Adhere: other
(Boston, Massachusetts) ^44^ | (30 months) | (16 practices)
2 general medicine clinics | --- | RCT | Patient Ed, Self-Mx, Facil relay, Org change | Dz: HbA1c, other
(unspecified US city) ^45^ | (1 year) | (148) | | Pat comp
4 university-affiliated VA clinics | --- | RCT | Patient Ed, Self-Mx, Pt Remind, Facil relay, Org change | Dz: HbA1c, other
(unspecified US city) ^46^ | (1 year) | (292)
Diabetes clinic, Vrije Universiteit Medical Center | 1997-1999 | RCT | Org change | Dz: HbA1c
(The Netherlands) ^47^ | (20 months) | (400)
9 primary health centers | --- | CBA | Patient Ed, Prvdr Ed, Facil relay, Org change | Dz: BP, other
(United Arab Emirates) ^48^ | (18 months) | (219, 9 practices)
General practices | 1992-1997 | CBA | Prvdr Ed, Facil relay, Audit & Fdbck | Dz: other
(The Netherlands) ^49^ | (5 years) | (478, 27 providers) | | Adhere: HbA1c, HTN/CAD, other
3 Turku area podiatry clinics | --- | RCT | Patient Ed, Org change | Dz: other
(Finland) ^50^ | (1 year) | (530) | | Pat comp
Pleasanton facility, Kaiser Permanente Medical Care Program | 1995-1997 | RCT | Patient Ed, Pt Remind, Org change | Dz: HbA1c
(N. California) ^51^ | (6 months) | (185) | | Pat comp
Sub-specialty diabetes clinic | 1996 | CBA | Org change | Dz: HbA1c, BP
(unspecified US city) ^52^ | (3 months) | (82) | | Adhere: HbA1c, Foot/Eye, other
Division of Community Internal Medicine, Mayo Clinic | 2000-2001 | RCT | Org change | Dz: HbA1c, other
(Minnesota) ^53^ | (6 months) | (727, 29 providers) | | Adhere: HbA1c, other
Division of Community Internal Medicine, Mayo Clinic | 2000-2001 | RCT | Pt Remind, Org change | Dz: HbA1c, other
(Minnesota) ^53^ | (6 months) | (752, 29 providers) | | Adhere: HbA1c, other
Diabetes clinic | --- | RCT | Patient Ed, Facil relay, Org change | Dz: HbA1c
(Canada) ^54^ | (6 months) | (46)
General practices | --- | CBA | Org change | Dz: other
(England) ^55^ | (16 months) | (218) | | Adhere: HbA1c
35 primary care practices | --- | RCT | Patient Ed, Self-Mx, Org change | Dz: HbA1c, other
(Seattle, Washington) ^56^ | (1 year) | (707, 35 practices) | | Adhere: Foot/Eye, other
2 community health centers | --- | RCT | Prvdr Ed | Adhere: HbA1c, Foot/Eye, other
(unspecified Northeast US city) ^57^ | (1 year) | (400, 2 practices)
2 community health centers | --- | RCT | Patient Ed, Prvdr Ed | Adhere: HbA1c, Foot/Eye, other
(unspecified Northeast US city) ^57^ | (1 year) | (400, 2 practices)
Australia ^58^ | --- | RCT | Prvdr Ed, Audit & Fdbck | Adhere: HbA1c, HTN/CAD, Foot/Eye, other
| (6 months) | (265, 160 providers)
Australia ^58^ | --- | RCT | Prvdr Ed, Audit & Fdbck | Adhere: HbA1c, HTN/CAD, Foot/Eye, other
| (6 months) | (256, 160 providers)
General medical clinic, Durham Dept of VA Medical Center | --- | RCT | Patient Ed, Self-Mx, Pt Remind, Facil relay, Org change | Dz: HbA1c, other
(North Carolina) ^59^ | (1 year) | (275)

* Pt Remind - patient reminder, Prvdr Remind - provider reminder, Org change - organizational change, Self-Mx — self-management, Facil Relay — facilitated relay of clinical data to providers, Patient Ed — patient education, Prvdr Ed — provider education, Audit & Fdbck — audit and feedback to provider Financial — financial or regulatory intervention

† Dz: measure of disease control; hemoglobin A1c (HbA1c), blood pressure (BP); other.Adhere: measure of provideradherence to guideline or recommendation for measurement of HbA1c (labeled simply HbA1c), management of hypertension or coronary artery disease (HTN/CAD); screening or referral for detection of complications involving the foot or eye (foot/eye); other: patient education/counseling measurement of other lab value Pat comp: patient compliance

Only four studies ^96^ – ^99^ (including one excluded at Stage 3) reported average change scores per patient (e.g., post-intervention HbA_1c_ - pre-intervention HbA_1c_) accompanied by a value for the standard deviation of the change score. These four studies contributed two values each (one per study group), permitting estimation of the correlation between baseline and followup values according to the equation: SD_x-y_ = SD_x_ ^2^ + SD_y_ ^2^ - 2*SD_x_*SD_y_*ρ, where ρ represents the correlation between the pre- and post-intervention measurements. The calculated values for ρ had a median of 0.64 [inter-quartile (IQ) range: 0.50,0.72]. Given this range of values for correlation within groups, baseline differences between the study groups were considered a necessary predictor in the regression analyses.

### Multiple Comparisons and A Priori Hypotheses

Meta-regression analysis amounts to studying the epidemiology of a population of trials. In other words, despite the experimental nature of the trial, this analysis is essentially observational. Moreover, the number of trials (in the range of 10 to 60, depending on the QI strategy and outcome being reported), while reasonable for a conventional meta-analysis addressing a focused question (Is Treatment A superior to Treatment B?) with one or two potential confounding variables, is relatively small for an analysis with at least 10 to 15 potential variables of interest. As outlined in Table 4 of Volume 1, Chapter 2, in this series, potential predictors of intervention success or failure include features of trial methodology, the setting in which the trial occurred, attitudes of clinicians towards the QI target, organizational support for the intervention, and many other potential predictors. Investigators were unable to adequately incorporate some of these into this analysis, while others proved too elusive to be abstracted in a consistent and accurate manner.

Table 4a Associations between improvements in glycemic control and provider adherence stratified by trial design

| Median Reduction in HbA_1c_ | | | Median Improvement in provider adherence
| [inter-quartile range]* | | | [inter-quartile range]*
| N=Number of comparisons | | | N=Number of comparisons
| All Comparisons | RCT | Non-RCT^†^ | All Comparisons | RCT | Non-RCT^†^
All QI types | 0.48 | 0.39 | 1.40 | 4.9 | 4.5 | 18.0
| [0.20, 1.38] | [0.10, 0.73] | [0.70, 1.78] | [3.8, 15.0] | [3.5, 5.4] | [17.2, 21.0]
| N=38 | N=28 | N=10 | N=17 | N=14 | N=3
Provider Education | 1.1 | 0.71 | 1.50 | 5.6 | 4.8 | 18.0
| [0.56, 1.5] | [0.41, 1.47] | [0.97, 2.13] | [4.2, 17.2] | [3.1, 8.0] | [17.2, 21.0]
| N=9 | N=5 | N=4 | N=11 | N=8 | N=3
Provider Reminders | 0.41 | 0.39 | 1.99 | 3.4 | 3.4 | ——
| [0.34, 0.97] | [0.32, 0.45] | —— | [2.2, 3.6] | [2.2, 3.6]
| N=7 | N=6 | N=1 | N=3 | N=3 | N=0
Facilitated relay | 0.48 | 0.40 | 1.40 | 4.9 | 4.9 | ——
| [0.33, 1.38] | [0.30, 0.60] | [0.50, 1.40] | —— | ——
| N=14 | N=9 | N=5 | N=1 | N=1 | N=0
Patient Education | 0.70 | 0.60 | 1.40 | 4.9 | 4.9 | ——
| [0.34, 1.45] | [0.25, 1.39] | [0.95, 1.70] | [4.7, 5.4] | [4.7, 5.4]
| N=18 | N=15 | N=3 | N=3 | N=3 | N=0
Self-management | 0.40 | 0.30 | 1.40 | 6.0 | 6.0 | ——
| [0.20, 0.60] | [0.20, 0.45] | [0.95, 1.40] | —— | ——
| N=13 | N=10 | N=3 | N=1 | N=1 | N=0
Patient reminders | 0.60 | 0.43 | 1.90 | 2.8 | 2.8 | ——
| [0.35, 1.29] | [0.28, 0.72] | [1.50, 2.35] | [1.0, 4.5] | [1.0, 4.5]
| N=11 | N=8 | N=3 | N=2 | N=2 | N=0
Audit & feedback | 0.71 | 0.56 | 1.40 | 5.6 | 5.0 | 20.2
| [0.41, 1.40] | [0.33, 0.90] | —— | [3.4, 16.4] | [3.2, 10.3] | [16.4, 23.9]
| N=5 | N=4 | N=1 | N=9 | N=7 | N=2*
Organizational Change | 0.60 | 0.25 | 1.4 | 4.7 | 4.5 | 18.0
| [0.10, 1.35] | [0.03, 0.68] | [1.1, 1.9] | [4.1, 5.7] | [4.0, 4.9] | ——
| N=27 | N=18 | N=9 | N=6 | N=5 | N=1

* When N=2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

† Non-RCT included 16 controlled before-after studies and 1 quasi-randomized trial.

Given the aforementioned considerations and the sheer number of comparisons considered in the analysis, any significant findings should be regarded as exploratory and solely for the purpose of generating hypotheses, regardless of adjustments to the threshold for statistical significance. In this context, more important than the actual correction is the degree to which significant findings relate to an a priori hypothesis. In the case of this review, the only specific hypotheses were as follows:

- Trial design may have a significant impact on results, with randomized trials expected to show lesser effect sizes
  Despite the epistemological superiority of randomized trials, the magnitude of bias introduced by well-conducted non-randomized trials and other observational research is surprisingly modest. Moreover, the direction and magnitude of bias do not appear to be consistent (i.e., observational studies may under-or over-estimate true effects to varying extents). ^100^ – ^102^ It should be noted, however, that comparisons of results from randomized and non-randomized trials have been used for clinical efficacy research, not for quality improvement research. The significance of this distinction is that potential confounders are far better known for the former, based on the results of previous clinical research and a much greater understanding of the relevant pathophysiology, than exists for our understanding of behavioral change, organizational theory, etc.
  Thus, QI trials may be more susceptible to confounding by unknown variables, both at the level of trial design and analysis. For this reason, the investigators expected study design to exert an influence on the results of QI studies. They had no hypothesis about the direction of this effect, apart from the likelihood that publication bias would exert a greater influence on non-randomized trials, and that the positive trials would be over-represented among the non-randomized trials to a greater degree than the randomized trials.
- Study period may be an important predictor, but the authors had no hypothesis about the direction of effect
  There are three reasons for which the study period was considered a potential predictor or confounder: showing an effect might have become more difficult over time if care has improved in response to previous QI studies (higher baseline adherence, as might occur over time, was in fact associated with smaller effects in the recent update of the Cochrane review of audit and feedback ^54^ ); study design has probably improved with time, as may be the case for intervention design (e.g., the type and number of QI strategies employed); regardless of baseline adherence, QI targets may have become harder to achieve because what counts as adherence has changed (e.g., guidelines recommend lower target levels for serum HbA_1c_, blood pressure, lipids) and the newer targets are generally more difficult to achieve.
  These factors could exert an influence opposite that of the effect, so the investigators had no hypothesis regarding the net impact of study period on QI trial results.
- Number of QI strategies
  The number of QI strategies employed is at least as important as the choice of strategies (e.g., multifaceted interventions are more likely to succeed than interventions using a single QI strategy ^103^ ). Two recent reviews—one of strategies to promote guideline implementation ^85^ and one on audit and feedback as a QI strategy ^54^ —have called into question the widely held view that multifaceted strategies are superior to single-faceted ones. The authors considered this hypothesis worthy of examination, in terms of its practical value to those engaged in QI work and research, and the likelihood that this review would involve sufficient data to address the question. (By contrast, the researchers expected relatively small numbers of studies for any particular QI type.)