# Introduction

## Background

In the past decade, diabetes mellitus (DM) has reached epidemic proportions in the United States. The disease now affects more than 17 million people nationwide. ^1^ Include undiagnosed cases and individuals with impaired glucose tolerance, and one in every seven Americans either has diabetes, or is at high risk for developing the disease. Equally disturbing, the prevalence of diabetes has increased by 60% since 1991, ^1^ and there is a direct correlation with the increase in obesity over the same period. ^2^ As a result, diabetes is likely to pose a major public health problem for decades to come. ^3^

The past decade also has played witness to major advances in diabetes care, beginning with the publication of the Diabetes Control and Complications Trial (DCCT) in 1993, ^4^ followed by the United Kingdom Prospective Diabetes Study (UKPDS) trials in the second half of the 1990s. ^5,^ ^6^ These studies clearly demonstrated that aggressive management of hyperglycemia significantly improves quality of life, while reducing morbidity and mortality. Effective treatment strategies also have been developed for the control of diabetes' principal comorbid conditions, hyperlipidemia and hypertension, ^7^ – ^9^ and for the screening and early treatment of complications such as retinopathy, neuropathy, nephropathy, and foot disease. ^10^ Since diabetes-related complications account for more than 200,000 deaths, 82,000 amputations, 38,000 new cases of end-stage renal disease, and 12,000 cases of blindness annually, the implementation of proven screening and treatment strategies could significantly reduce morbidity and mortality. ^1^ Exact projections are difficult to establish, but evidence from the UKPDS trials shows that a mere one point reduction in the average hemoglobin A_1c_ (HbA_1c_) could lead to a 25% decrease in diabetes-related deaths. ^11^ Morevoer, the National Committee for Quality Assurance estimates that improved glycemic control could prevent 13,600 deaths annually in the U.S. alone. ^12^

## The Quality Gap

Diabetes care in the U.S. consistently has failed to meet recommended quality standards. Data collected between 1988 and 1995 (derived from the Center for Disease Control's population-based Behavioral Risk Factor Surveillance System [BRFSS], as well as the National Health and Nutrition Examination [NHANES] surveys) reveal significant quality gaps in the treatment of diabetes and in screening for diabetes-related complications. Nearly one in five diabetics has poor glycemic control (HbA_1c_ level > 9.5%), more than one-third have elevated blood pressure (> 140/90 mmHg) and more than half of diabetes patients have elevated LDL-cholesterol levels (even under the more liberal National Cholesterol Education Program [NCEP-II] guidelines, with unacceptable levels defined as > 130 mg/dl.).13 Diabetics also do not receive appropriate screening measures: only 28% receive the recommended HbA_1c_ measurements more than once yearly, while just 55% obtain annual foot examinations, and 63% submit to an annual dilated eye examination. ^13^ These data were collected before publication and widespread distribution of the DCCT and UKPDS results, but more recent data do not indicate significant improvement. ^14^ Racial and ethnic disparities persist as well. African Americans and Hispanics are significantly more likely to die of diabetes-related complications than are Caucasians, ^1^ while Native Americans and other vulnerable populations suffer under a disproportionate burden of diabetes and diabetes-related morbidity and mortality. ^15^

The National Committee on Quality Assurance (NCQA) used similar criteria to compile its Health Plan Employer Data Information Set (HEDIS^®^), the basis for its annual “State of Health Care Quality” report. The HEDIS data uses benchmarks established in 1997 by the Diabetes Quality Improvement Project, a consortium of 13 public and private organizations including the American Diabetes Association. In 2001, HEDIS data show that among patients with commercial health insurance, 37% had an HbA_1c_ greater than 9.5%, 45% had a blood pressure of over 140/90 mmHg, and 50% had LDL-cholesterol of over 130 mg/dl.12 Process measures also revealed disconcerting lapses: 19% of diabetics did not receive HbA_1c_ measurements, 48% did not receive retinal exams, and nephropathy screenings were not conducted for 54% of diabetic patients. ^12^ Thus, despite the continuing advances in diabetes treatment and an increased focus on bridging quality gaps, many patients who should have adequate access to care are not receiving guideline-concordant care.

Outpatient care for diabetes exemplifies the challenges of, and opportunities for, chronic disease management. Involving patients in their own care, particularly with regard to education and self-management, can improve health outcomes, as well as the diabetic patient's quality of life. ^10^ However, the quality gaps that persist in the treatment and secondary prevention screening processes demonstrate the pressing need to improve medical providers' adherence to standards of care in both of these areas. Management priorities have focused traditionally on glycemic control, but control of hypertension and hyperlipidemia is of equal importance, given the high morbidity and mortality from cardiovascular disease in diabetic patients. Regular monitoring of long-term glycemic control and hyperlipidemia also should accompany traditional secondary prevention measures such as screening for retinopathy (with dialation), neuropathy (with foot exams) and nephropathy (with urine microalbuminuria); smoking cessation; as well as influenza and pneumococcal vaccination.

A prior systematic review of this topic area ^16^ examined articles from MEDLINE^®^, the Cochrane Collaboration's Effective Practice and Organisation of Care database (EPOC), and related databases. The comprehensive search strategy identified a total of 41 articles involving professional and/organizational interventions intended to improve diabetes management, though it should be noted the review has not been updated to include articles published since 1999. The results of the review suggest that multifaceted interventions and interventions involving organizational change (i.e., those involving a change in the structure or delivery of health care) could have a positive effect on key processes of care, though analysis of the identified studies was purely descriptive.

With the exception of a recent review of disease management strategies, ^17^ prior systematic reviews have not included any quantitative synthesis of quality improvement (QI) strategies, presumably because of study heterogeneity along multiple dimensions (e.g., trial design, study, setting, variations in definitions of “provider education,” “audit and feedback,” “disease management,” and other labels for QI strategies), as well as relatively small numbers of trials. In this review, the authors have expanded upon the previous qualitative and systematic review of strategies to improve diabetes care ^16^ with the inclusion of more recent studies, and through the use of quantitative analysis to better characterize the effectiveness of particular QI strategies. They have also analyzed more general conclusions such as the relative impact of multifaceted interventions or organizational interventions versus strategies targeting only behavioral change in providers.

## Settings Goals for Clinical Care vs. Performance Measurement

Recognizing the urgent need to improve the quality of diabetes care, the National Diabetes Quality Improvement Alliance (NDQIA), a consortium of prominent organizations involved with diabetic patient care and overall health care quality improvement efforts,^*^ released updated guidelines in May, 2003. ^18^ The NDQIA report ^18^ distinguishes between targets appropriate for guiding the treatment of individual patients versus targets appropriate for measuring the performance of a clinic or larger health care delivery system (Appendix A). For instance, the NDQIA endorses the HbA_1c_ < 7.0% as the optimal target for clinical care but, for purposes of performance measurement, focuses on the percentage of patients with HbA_1c_ below 9.0%. This focus on “poor control as it pertains to performance measurement” versus “good control as it pertains to individual patient care” reflects a recognition of various factors other than quality issues that can influence the percentage of patients achieving optimal control. Further examples of this awareness include variations in the degree to which local laboratories follow guidelines for assay selection, ^19^ comorbid conditions, frequency and severity of hypoglycemia, and patient preferences, among other factors.

* Organizations include the Agency for Healthcare Research and Quality, American Academy of Family Physicians, American Association of Clinical Endocrinologists, American College of Physicians, American Diabetes Association, American Medical Association, Centers for Disease Control and Prevention, Centers for Medicare & Medicaid Services, National Institute of Diabetes and Digestive and Kidney Diseases, and U.S. Department of Veterans Affairs, among others.

Studies included in this review have a tendency to specify the targets found in clinical guidelines as their QI goals—although this was not part of the authors' inclusion criteria. Rather, the outcomes have been structured to accommodate expected variations in QI targets. These outcomes are explained in Chapter 2, Methods.

## Key Questions

In this review, the literature on quality improvement for diabetes care has been carefully synthesized in an effort to address three questions:

1 Are there QI strategies that improve physicians' treatment of diabetes and its comorbidities?
  - Can the control of hyperglycemia, hyperlipidemia, and hypertension be improved?
  - Can microvascular and macrovascular complications be prevented?
2 Are there QI strategies that improve provider adherence to recommended monitoring?
  - Which interventions improve physicians' adherence to long-term glucose monitoring, to screening for hyperlipidemia and hypertension, and to screening for complications such as retinopathy, neuropathy, and nephropathy?
3 Are there QI strategies that improve patients' adherence to treatment and self-care measures?

Although screening and prevention of diabetes have become increasingly important, these interventions lack a clear evidence base indicating a reduction in morbidity and mortality. ^10^ Accordingly, the authors did not address questions related to screening for diabetes in this review. (By contrast, the impact of screening for elevated blood pressure is well established, so screening interventions are included in Volume 3, the hypertension review.)