# Additional tables for diabetes results and analysis

## Tables H1–H3. Re-analysis of adherence in terms of maximum rather than median effect reported by each study

In the main analysis, we pooled the various adherence outcomes reported by the included studies into a general provider adherence outcome. For each study, this measure was based on the adherence outcome exhibiting the median effect.

In Appendix Tables H1–H3, we show the results obtained if, instead of taking the outcome with median effect, one selects the outcome with maximum effect (i.e., the outcome for which the intervention group showed the greatest increase in adherence above any increases in the control group).

The purpose of the comparison is not the different magnitudes size between the maximum and median adherence (as these are expected to differ in this regard) but rather, the degree to which the patterns across QI types, strata of sample size and trial design are the same. In other words, it is unlikely that the relationships discussed in the main analysis simply reflect the definition of the generalized adherence outcome in terms of the median effect associated with each study. The same general relationships emerge on analyzing the studies in terms of the maximum impact on adherence achieved by each study.

## Tables H4a–c. Alternate classification scheme for numbers of QI strategies per intervention

The main analysis showed a benefit for intervention with at least 2 QI strategies compared to single-faceted ones. Since this finding relates to one of our a priori hypotheses (that multi-faceted interventions achieve greater impact than single faceted ones), we further explored this question by reclassifying each intervention using a scheme similar to that used by other authors, in which major subtypes are regarded as their own category. Specifically, we replaced the broad category of provider education with separate categories for workshops or meeting, educational outreach or academic detailing, and distribution of educational materials. Similarly, we promoted disease management, team or personnel changes, and changes to the existing medical record system to their own categories, rather than pooling them within the broad category of organizational change.

Table H1a Association between maximum improvements in provider adherence and type of quality improvement strategy stratified by study sample size (median adherence included for comparison)

| Median Improvement in clinician adherence | Maximum Improvement in provider adherence
| [inter-quartile range] | [inter-quartile range]
| N=Number of trials | N=Number of trials
| All Trials | All Trials | Trials with sample size in lowest quartile | Trials with sample size in lower 2 quartiles | Trials with sample size in upper 2 quartiles | Trials with sample size in highest quartile
All QI types | 4.8 | 11.6 | 21.8 | 25.9 | 11.0 | 10.8
| [3.8, 15.0] | [7.0, 23.7] | [21.4,30.9] | [21.2,37.5] | [6.5,13.5] | [6.5,12.6]
| N=17 | N=17 | N=3 | N=6 | N=11 | N=8
Provider Education | 5.6 | 21.8 | 21.8 | 30.0 | 11.3 | 11.3
| [4.15, 17.2] | [11.3,28.5] | [21.4,30.9] | [21.8,40.0] | [11.0,2.07] | [10.9,14.6]
| N=11 | N=11 | N=3 | N=5 | N=6 | N=4
Provider Reminders | 3.4 | 11.0 | —— | —— | 11.0 | 13.0
| [2.2, 3.6] | [10.8,13.2] | | | [10.8,13.2] | [10.5,15.4]
| N=3 | N=3 | N=0 | N=0 | N=3 | N=2
Facilitated relay | 4.85 | 4.85 | —— | 4.85 | —— | ——
| —— | —— | | ——
| N=1 | N=1 | N=0 | N=1 | N=0 | N=0
Patient Education | 4.9 | 6.0 | 40.0 | 22.4 | 6.0 | ——
| [4.7, 5.4] | [5.4,23.0] | —— | [4.9,40.0] | ——
| N=3 | N=3 | N=1 | N=2 | N=1 | N=0
Self-management | 6.0 | 6.0 | —— | —— | 6.0 | ——
| —— | —— | | | ——
| N=1 | N=1 | N=0 | N=0 | N=1 | N=0
Patient reminders | 2.8 | 9.0 | | | 9.0 | 7.0
| [1.0,4.5] | [7.0,11.0] | | | [7.0,11.0] | ——
| N=2 | N=2 | N=0 | N=0 | N=2 | N=1
Audit & feedback | 5.6 | 15.4 | 21.8 | 31.8 | 11.6 | 11.6
| [3.4, 16.4] | [11.0,23.7] | —— | [21.8,41.7] | [11.0,19.6] | [11.0,15.4]
| N=9 | N=9 | N=1 | N=2 | N=7 | N=5
Organizational Change | 4.7 | 6.5 | 4.9 | 17.4 | 6.5 | 6.0
| [4.1, 5.7] | [5.3,10.0] | —— | [4.9,30.0] | [5.8,8.0] | [5.0,7.0]
| N=6 | N=6 | N=1 | N=2 | N=4 | N=2

† For each study, the general provider adherence outcome captured the adherence outcome with the median effect size reported by that study. In this set of appendix tables, we show the results obtained if, instead of taking the outcome with median effect, one selects the outcome with maximum effect (i.e., the outcome for which the intervention group showed the greatest increase in adherence above any increases in the control group).

th When N=2, square brackets show the actual results of each study rather than interpolated 25 and 75 percentiles.

Table H1b Associations between improvements in glycemic control and provider adherence stratified by trial design (median adherence included for comparison)

| Median Improvement in provider adherence | | | Maximum Improvement in provider adherence
| [inter-quartile range*] | | | [inter-quartile range*]
| N=Number of trials | | | N=Number of trials
| All Trials | RCT | Non-RCT^†^ | All Trials | RCT | Non-RCT^†^
All QI types | 4.9 | 4.5 | 18.0 | 11.6 | 11.0 | 30.0
| [3.8, 15.0] | [3.5, 5.4] | [17.2, 21.0] | [7.0,23.7] | [6.3,19.6] | [28.5,35.9]
| N=17 | N=14 | N=3 | N=17 | N=14 | N=3
Provider Education | 5.6 | 4.8 | 18.0 | 21.8 | 16.3 | 30.0
| [4.2, 17.2] | [3.1,8.0] | [17.2, 21.0] | [11.3,28.5] | [11.0,22.3] | [28.5,35.9]
| N=11 | N=8 | N=3 | N=11 | N=8 | N=3
Provider Reminders | 3.4 | 3.4 | —— | 11.0 | 11.0 | ——
| [2.2, 3.6] | [2.2, 3.6] | | [10.8,13.2] | [10.8,13.2]
| N=3 | N=3 | N=0 | N=3 | N=3 | N=0
Facilitated relay | 4.9 | 4.9 | —— | 4.85 | 4.85 | ——
| —— | —— | | —— | ——
| N=1 | N=1 | N=0 | N=1 | N=1 | N=0
Patient Education | 4.9 | 4.9 | —— | 6.0 | 6.0 | ——
| [4.7, 5.4] | [4.7, 5.4] | | [5.4,23.0] | [5.4,23.0]
| N=3 | N=3 | N=0 | N=3 | N=3 | N=0
Self-management | 6.0 | 6.0 | —— | 6.0 | 6.0 | ——
| —— | —— | | —— | ——
| N=1 | N=1 | N=0 | N=1 | N=1 | N=0
Patient reminders | 2.8 | 2.8 | —— | 9.0 | 9.0 | ——
| [1.0,4.5] | [1.0, 4.5] | | [7.0,11.0] | [7.0,11.0]
| N=2 | N=2 | N=0 | N=2 | N=2 | N=0
Audit & feedback | 5.6 | 5.0 | 20.2 | 15.4 | 11.6 | 34.3
| [3.4, 16.4] | [3.2, 10.3] | [16.4,23.9] | [11.0,23.7] | [11.0,18.6] | [26.9,41.7]
| N=9 | N=7 | N=2* | N=9 | N=7 | N=2*
Organizational Change | 4.7 | 4.5 | 18.0 | 6.5 | 6.0 | 30.0
| [4.1, 5.7] | [4.0, 4.9] | —— | [5.3,10.0] | [5.0,7.0] | ——
| N=6 | N=5 | N=1 | N=6 | N=5 | N=1

* When N=2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

† Non-RCT included 16 controlled before-after studies and 1 quasi-randomized trial.

Table H1c Impacts on glycemic control and provider adherence stratified by trial design and sample size (median adherence included for comparison)

| | All sizes | Trials with sample size in lowest quartile | Trials with sample size in lower 2 quartiles | Trials with sample size in upper 2 quartiles | Trials with sample size in highest quartile
Median Improvement in provider adherence (%) | All trial designs | 4.8 | 4.5 | 10.6 | 4.5 | 4.2
[inter-quartile range^†^] | | [3.8, 15.0] | [2.8, 11.4] | [4.6, 17.6] | [3.6, 5.8] | [3.7, 5.2]
N=Number of trials | | N=17 | N=3 | N=6 | N=11 | N=8
| RCTs | 4.5 | 4.5 | 4.7 | 4.3 | 4.3
| | [3.5,5.5] | [2.8,11.4] | [3.6,8.2] | [3.5,5.5] | [3.7,5.2]
| | N=14 | N=3 | N=4 | N=10 | N=8
| Non-RCTs | 18.0 | | 17.2 | 23.9
| | [17.2,21.0] | | [16.4,18.0] | ——
| | N=3 | N=0 | N=2 | N=1 | N=0
Maximum Improvement in provider adherence (%) | All trial designs | 11.6 | 21.8 | 25.9 | 11.0 | 10.8
[inter-quartile range^†^] | | [7.0, 23.7] | [21.4,30.9] | [21.2,37.5] | [6.5,13.5] | [6.5,12.6]
N=Number of trials | | N=17 | N=3 | N=6 | N=11 | N=8
| RCTs | 11.0 | 21.8 | 21.4 | 10.8 | 10.8
| | [6.3,19.6] | [21.4,30.9] | [17.0,26.4] | [6.3,11.5] | [6.5,12.6]
| | N=14 | N=3 | N=4 | N=10 | N=8
| Non-RCTs | 30.0 | | 35.9 | 26.9
| | [28.5,35.9] | | [30.0,41.7] | ——
| | N=3 | N=0 | N=2 | N=1 | N=0

Table H2a Association between improvement in provider adherence and number of QI strategies stratified by study sample size (median adherence included for comparison)

Number of QI Strategies | Median Improvement in Provider Adherence (%) | Maximum Improvement in Provider Adherence (%)
| [inter-quartile range] | [inter-quartile range]
| N=Number of trials | N=Number of trials
| All Trials | All Trials | Trials with sample size in lowest quartile | Trials with sample size in lower 2 quartiles | Trials with sample size in upper 2 quartiles | Trials with sample size in highest quartile
Any number (for comparison purposes) | 4.8 | 11.6 | 21.8 | 25.9 | 11.0 | 10.8
| [3.8, 15.0] | [7.0, 23.7] | [21.4,30.9] | [21.2,37.5] | [6.5,13.5] | [6.5,12.6]
| N=17 | N=17 | N=3 | N=6 | N=11 | N=8
1 strategy only | 3.0 | 5.0 | 21.0 | 21.0 | 4.5 | 4.5
| [2.0,3.5] | [4.5,13.0] | —— | —— | [4.0,5.0] | [4.0,5.0]
| N=3 | N=3 | N=1 | N=1 | N=2 | N=2
≥ 2 strategies | 5.3 | 13.5 | 30.9 | 30.0 | 11.0 | 11.3
| [4.5,16.1] | [10.6,26.1] | [21.8,40.0] | [21.8,40.0] | [10.5,15.4] | [10.6,14.5]
| N=14 | N=14 | N=2 | N=5 | N=9 | N=6
≥ 3 strategies | 4.9 | 6.0 | | 4.9 | 8.5
| [2.9,5.4] | [5.4,8.5] | | —— | [6.0,11.0]
| N=3 | N=3 | N=0 | N=1 | N=2 | N=0
≥ 4 strategies | 1.0 | 11.0 | | | 11.0
| —— | —— | | | ——
| N=1 | N=1 | N=0 | N=0 | N=1 | N=0
5 strategies * | 1.0 | 11.0 | | | 11.0
| —— | —— | | | ——
| N=1 | N=1 | N=0 | N=0 | N=1 | N=0

* No study involved an intervention with more than 5 QI types.

Table H2b Associations between number of quality improvement strategies and improvements in glycemic control and provider adherence stratified by trial design

| Median Reduction in HbA_1c_ | | | Maximum Improvement in provider adherence
| [inter-quartile range*] | | | [inter-quartile range*]
| N=Number of trials | | | N=Number of trials
| All Trials | RCT | Non-RCT^†^ | All Trials | RCT | Non-RCT^†^
Any number (for comparison purposes) | 4.9 | 4.5 | 18.0 | 11.6 | 11.0 | 30.0
| [3.8, 15.0] | [3.5, 5.4] | [17.2, 21.0] | [7.0,23.7] | [6.3,19.6] | [28.5,35.9]
| N=17 | N=14 | N=3 | N=17 | N=14 | N=3
Single strategy only | 3.0 | 3.0 | | 5.0 | 5.0
| [2.0,3.5] | [2.0,3.5] | | [4.5,13.0] | [4.5,13.0]
| N=3 | N=3 | N=0 | N=3 | N=3 | N=0
≥ 2 strategies | 5.3 | 4.9 | 18.0 | 13.5 | 11.0 | 30.0
| [4.5,16.1] | [4.2,5.8] | [17.2,21.0] | [10.6,26.1] | [8.8,18.6] | [28.5,35.9]
| N=14 | N=11 | N=3 | N=14 | N=11 | N=3
≥ 3 strategies | 4.9 | 4.9 | | 6.0 | 6.0
| [2.9, 5.4] | [2.9, 5.4] | | [5.4,8.5] | [5.4,8.5]
| N=3 | N=3 | N=0 | N=3 | N=3 | N=0
≥ 4 strategies | 1.0 | 1.0 | | 11.0 | 11.0
| —— | —— | | —— | ——
| N=1 | N=1 | N=0 | N=1 | N=1 | N=0
5 strategies* | 1.0 | 1.0 | | 11.0 | 11.0
| —— | —— | | —— | ——
| N=1 | N=1 | N=0 | N=1 | N=1 | N=0

* No study involved an intervention with more than 5 QI types.

Table H3a Median and maximum improvements in provider adherence associated with specific substrategies of organizational change stratified by study design

| Median Reduction in HbA_1c_ | | | Maximum Improvement in provider adherence
| [inter-quartile range *] | | | [inter-quartile range]
| N=Number of trials | | | N=Number of trials
Type of organizational change | All Trials | RCT | Non-RCT | All Trials | RCT | Non-RCT
All QI types | 4.85 | 4.5 | 18.0 | 11.6 | 11.0 | 30.0
| [3.8,15.03] | [3.5,5.45] | [17.2,20.95] | [7.0,23.7] | [6.3,19.6] | [28.5,35.9]
| N=17 | N=14 | N=3 | N=17 | N=14 | N=3
Any type of organizational change | 4.7 | 4.5 | 18.0 | 6.5 | 6.0 | 30.0
| [4.1,5.7] | [4.0,4.9] | —— | [5.3,10.0] | [5.0,7.0] | ——
| N=6 | N=5 | N=1 | N=6 | N=5 | N=1
No organizational change | 5.0 | 4.5 | 20.2 | 21.0 | 15.4 | 34.3
| [3.6,15.7] | [3.4,5.6] | [16.4,23.9] | [11.3,25.3] | [11.0,21.8] | [26.9,41.7]
| N=11 | N=9 | N=2 | N=11 | N=9 | N=2
Disease/case management | 4.9 | 4.9 | | 4.9 | 4.9
| —— | —— | | —— | ——
| N=1 | N=1 | N=0 | N=1 | N=1 | N=0
No disease/case management | 4.8 | 4.5 | 18.0 | 13.5 | 11.0 | 30.0
| [3.7,15.4] | [3.4,5.6] | [17.2,21.0] | [9.6,24.5] | [7.0,21.0] | [28.5,35.9]
| N=16 | N=13 | N=3 | N=16 | N=13 | N=3
No disease/case management (some other organizational change present) | 4.5 | 4.3 | 18.0 | 7.0 | 6.5 | 30.0
| [4.0,6.0] | [3.3,4.9] | —— | [6.0,11.0] | [5.8,8.0] | ——
| N=5 | N=4 | N=1 | N=5 | N=4 | N=1
Team/staffing changes | 12.0 | 6.0 | 18.0 | 18.0 | 6.0 | 30.0
| [6.0,18.0] | —— | —— | [6.0,30.0] | —— | ——
| N=2 | N=1 | N=1 | N=2 | N=1 | N=1
No team/staffing changes | 4.5 | 4.5 | 20.2 | 11.6 | 11.0 | 34.3
| [3.6,10.3] | [3.4,5.0] | [16.4,23.9] | [8.8,22.8] | [7.0,21.0] | [26.9,41.7]
| N=15 | N=13 | N=2 | N=15 | N=13 | N=2
No team/staffing Changes (some other organizational change present) | 4.3 | 4.3 | | 6.0 | 6.0
| [3.3,4.6] | [3.3,4.6] | | [5.0,8.0] | [5.0,8.0]
| N=4 | N=4 | N=0 | N=4 | N=4 | N=0
Medical record changes | 1.0 | 1.0 | | 11.0 | 11.0
| —— | —— | | —— | ——
| N=1 | N=1 | N=0 | N=1 | N=1 | N=0
No medical record changes | 4.9 | 4.5 | 18.0 | 13.5 | 11.0 | 30.0
| [4.0,15.4] | [3.8,5.6] | [17.2,21.0] | [16.8,24.5] | [6.0,21.0] | [28.5,35.9]
| N=16 | N=13 | N=3 | N=16 | N=13 | N=3
No medical record changes (some other organizational change present) | 4.9 | 4.7 | 18.0 | 6.0 | 5.5 | 30.0
| [4.5,6.0] | [4.4,5.1] | —— | [5.0,7.0] | [5.0,6.3] | ——
| N=5 | N=4 | N=1 | N=5 | N=4 | N=1

* No study involved an intervention with more than 5 QI types.

Table H3b Median and maximum improvements in provider adherence associated with various roles for clinical information systems

| Median Reduction in HbA_1c_ | | | Maximum Improvement in provider adherence
| [inter-quartile range *] | | | [inter-quartile range]
| N=Number of trials | | | N=Number of trials
Type of clinical information system (CIS) | All Trials | RCT | Non-RCT | All Trials | RCT | Non-RCT
All Trials | 0.48 | 0.39 | 1.4 | 11.6 | 11.0 | 30.0
| [0.20, 1.38] | [0.1,0.73] | [1.1,1.78] | [7.0,23.7] | [6.3,19.6] | [28.5,35.9]
| N=38 | N=28 | N=10 | N=17 | N=14 | N=3
Any CIS | 0.9 | 0.4 | 1.4 | 7.0 | 7.0 | ——
| [0.3,1.42] | [0.1,0.8] | [1.33,1.92] | [6.0,10.5] | [6.0,10.5]
| N=20 | N=12 | N=8 | N=5 | N=5 | N=0
No CIS | 0.35 | 0.3 | 0.53 | 21.4 | 11.6 | 30.0
| [0.2,0.59] | [0.15,0.65] | [0.5,0.56] | [11.0,27.7] | [11.0,21.8] | [28.5,35.9]
| N=18 | N=16 | N=2 | N=12 | N=9 | N=3
Identification of eligible participants | 0.35 | 0.1 | 1.4 | 6.0 | 6.0 | ——
| [0.1,0.96] | [0.1,0.6] | —— | [5.5,6.5] | [5.5,6.5]
| N=6 | N=5 | N=1 | N=3 | N=3 | N=0
No identification of eligible participants | 0.48 | 0.4 | 1.4 | 18.2 | 11.6 | 30.0
| [0.21,1.4] | [0.2,0.76] | [0.56,1.9] | [11.0,26.1] | [10.8,21.4] | [28.5,35.9]
| N=32 | N=23 | N=9 | N=14 | N=11 | N=3
No identification of eligible participants (some other role for CIS present ) | 1.25 | 0.41 | 1.40 | 13.0 | 13.0 | ——
| [0.401.49] | [0.39,1.09] | [1.25,1.95] | [10.5,15.4] | [10.5,15.4]
| N=14 | N=7 | N=7 | N=2 | N=2 | N=0
Reminder system | 0.71 | 0.4 | 1.95 | 10.5 | 10.5 | ——
| [0.39,1.69] | [0.24,0.56] | [1.7,2.19] | [8.8,13.0] | [8.8,13.0]
| N=11 | N=7 | N=4 | N=3 | N=3 | N=0
No reminder system | 0.47 | 0.3 | 0.98 | 16.3 | 11.0 | 30.0
| [0.15,1.19] | [0.1,0.8] | [0.52,1.4] | [7.3,26.1] | [5.5,21.4] | [28.5,35.9]
| N=27 | N=21 | N=6 | N=14 | N=11 | N=3
No reminder system (some other role for CIS present ) | 1.08 | 0.60 | 1.40 | 5.5 | 5.5 | ——
| [0.10,1.40] | [0.10,1.08] | [1.08,1.40] | [5.0,6.0] | [5.0,6.0]
| N=9 | N=5 | N=4 | N=2 | N=2 | N=0
Computerized decision support system (CDSS) | 1.1 | 0.24 | 1.99 | 13.0 | 13.0 | ——
| [0.37,1.99] | [0.1,0.37] | [1.55,2.4] | [10.5,15.4] | [10.5,15.4]
| N=5 | N=2 | N=3 | N=2 | N=2 | N=0
No CDSS | 0.47 | 0.4 | 1.4 | 11.6 | 11.0 | 30.0
| [0.2,1.30] | [0.12,0.78] | [0.53,1.4] | [6.5,25.3] | [5.8,21.2] | [28.5,35.9]
| N=33 | N=26 | N=7 | N=15 | N=12 | N=3
No CDSS (some other role for CIS present ) | 0.71 | 0.51 | 1.40 | 6.0 | 6.0 | ——
| [0.25,1.40] | [0.17,0.99] | [1.40,1.40] | [5.5,6.5] | [5.5,6.5]
| N=15 | N=10 | N=5 | N=3 | N=3 | N=0
Audit system | 1.4 | 0.8 | 1.4 | 15.4 | 15.4 | ——
| [0.75,1.45] | [0.1,1.5] | —— | —— | ——
| N=3 | N=2 | N=1 | N=1 | N=1 | N=0
No Audit system | 0.47 | 0.39 | 1.4 | 11.3 | 11.0 | 30.0
| [0.2,1.2] | [0.12,0.68] | [0.56,1.9] | [6.8,24.5] | [6.0,21.0] | [28.5,35.9]
| N=35 | N=26 | N=9 | N=16 | N=13 | N=3
No Audit system (some other role for CIS present ) | 0.71 | 0.40 | 1.40 | 6.5 | 6.5 | ——
| [0.37,1.40] | [0.17,0.68] | [1.25,1.95] | [5.8,7.9] | [5.8,7.9]
| N=17 | N=10 | N=7 | N=4 | N=4 | N=0

* When N=2, square brackets show the actual results of each study rather than interpolated inter-quartile range.

Table H4a Association between improvement in glycemic control and number of quality improvement strategies stratified by study sample size, but with number of QI strategies including important substrategies

| Median Reduction in HbA_1c_
| [inter-quartile range]
| N=Number of trials
Number of QI Strategies * | All Trials | Trials with sample size in lowest quartile | Trials with sample size in lower 2 quartiles | Trials with sample size in upper 2 quartiles | Trials with sample size in highest quartile
Any number of strategies | 0.48 | 1.35 | 0.80 | 0.21 | 0.10
| [0.20, 1.38] | [0.60,1.48] | [0.41, 1.44] | [0.10, 0.60] | [0.10, 0.33]
| N=38 | N=10 | N=19 | N=19 | N=10
1 strategy only | 0.00 | -0.20 ^ˆ^ | 0.15 | 0.00 | 0.00
| [0.0,0.10] | —— | [0.10,0.20] | [0.00,0.11] | [0.00,0.00]
| N=5 | N=1 | N=2^§^ | N=3 | N=2
≥ 2 strategies | 0.60 | 1.40 | 1.08 | 0.34 | 0.15
| [0.30, 1.40] | [0.71,1.50] | [0.47, 1.47] | [0.10, 0.73] | [0.10, 0.40]
| N= 33 | N=9 | N=17 | N=16 | N=8
≥ 3 strategies | 0.66 | 1.35 | 1.19 | 0.55 | 0.35
| [0.33, 1. 40] | [1.15, 1.40] | [0.53, 1.40] | [0.20, 1.18] | [0.17, 0.53]
| N=22 | N=4 | N=10 | N=12 | N=4
≥ 4 strategies | 0.6 | 0.71 | 0.59 | 0.6 | 0.50
| [0.41,1.1] | —— | [0.43,0.99] | [0.4, 1.5] | [0.35,0.55]
| N=13 | N=1 | N=6 | N=7 | N=3
≥ 5 strategies | 0.71 | 0.71 | 0.71 | 0.85 | 0.40
| [0.53,1.29] | —— | [0.59,1.09] | [0.50,1.53] | [0.20,0.60]
| N=7 | N=1 | N=3 | N=4 | N=2
6 strategies* | 1.09 | 0.71 | 1.09
| [0.71,1.47] | —— | [0.71,1.47]
| N=2 | N=1 | N=2 | N=0 | N=0

* Under this alternate classification of the QI strategies, Five studies were still single-faceted, ^1^ – ^5^ but the median number of strategies increased from two to three and the maximum number of strategies increased from five to six (seen in two comparisons ^6,^ ^7^ ).

ˆ All changes were standardized to reflect reductions. Thus, the negative sign here indicates an increase in serum HbA_1c_

† When N=2, the numbers in square brackets reflect the results for each of the two studies rather than the inter-quartile range.

Table H4b Association between improvement in provider adherence and number of quality improvement strategies stratified by study sample size, but with number of QI strategies including important subtypes*

| Median Improvement in Provider Adherence (%)
| [inter-quartile range]
| N=Number of trials
Number of QI Strategies | All Trials | Trials with sample size in lowest quartile | Trials with sample size in lower 2 quartiles | Trials with sample size in upper 2 quartiles | Trials with sample size in highest quartile
Any number (for comparison purposes) | 4.9 | 5.2 | 5.2 | 4.5 | 4.5
| [3.8, 15.0] | [4.4, 8.8] | [4.1, 15.8] | [3.8, 6.0] | [4.0, 5.0]
| N=17 | N=4 | N=8 | N=9 | N=5
1 strategy only | 3.0 | 3.0 | 3.0 | 4.0 | 4.0
| [3.0,4.0] | —— | —— | —— | ——
| N=2^ˆ^ | N=1 | N=1 | N=1 | N=1
≥ 2 strategies | 5.0 | 5.6 | 5.6 | 4.8 | 4.8
| [4.2,15.7] | [5.2,12.0] | [4.7,16.7] | [3.7,8.6] | [4.2,8.3]
| N=15 | N=3 | N=7 | N=8 | N=4
≥ 3 strategies | 5.6 | 5.6 | 5.6 | 5.5 | 11.5
| [4.7,16.5] | [5.2,12.0] | [4.7,16.7] | [4.0,9.0] | [5.0,18.0]
| N=11 | N=3 | N=7 | N=4 | N=2
≥ 4 strategies | 4.5 | —— | 4.5 | 9.5 | 18.0
| [2.8,11.3] | | —— | [1.0,18.0] | ——
| N=3 | N=0 | N=1 | N=2 | N=1
≥ 5 strategies | 1.0 | —— | —— | 1.0 | ——
| —— | | | ——
| N=1 | N=0 | N=0 | N=1 | N=0
6 strategies | —— | —— | —— | —— | ——
| N=0 | N=0 | N=0 | N=0 | N=0

* Analogous to Table 5b, but with major substrategies within provider education and organizational change counted as separate strategies. Specifically, the broad category of provider education has been replaced by three categories (workshops or meetings, distribution of educational materials, and educational outreach) and organizational change has been replaced by three strategies (disease or case management, changes to team structure or personnel, changes to medical records system, and “other organizational change”).

ˆ When N=2, the numbers in square brackets reflect the results for each of the two studies rather than the inter-quartile range.

Table H4c Associations between number of QI strategies and improvements in glycemic control and provider adherence stratified by trial design, but with number of QI strategies including important subtypes

| Median Reduction in HbA_1c_ | | | Median Improvement in provider adherence
| [inter-quartile range*] | | | [inter-quartile range*]
| N=Number of trials | | | N=Number of trials
| All Trials | RCT | Non-RCT^†^ | All Trials | RCT | Non-RCT^†^
Any number (for comparison purposes) | 0.48 | 0.39 | 1.4 | 4.9 | 4.5 | 18.0
| [0.20, 1.38] | [0.10, 0.73] | [0.70, 1.78] | [3.8, 15.0] | [3.5, 5.4] | [17.2, 21.0]
| N=38 | N=28 | N=10 | N=17 | N=14 | N=3
1 strategy only | 0.00 | 0.00 | —— | 3.0 | 3.0 | ——
| [0.0,-0.1] | [0.0,-0.1] | | [3.0,4.0] | [3.0,4.0]
| N=5 | N=5 | N=0 | N=2 | N=2 | N=0
≥ 2 strategies | 0.60 | 0.41 | 1.4 | 5.0 | 4.7 | 18.0
| [0.30, 1.40] | [0.25,0.94] | [0.7,1.78] | [4.2,15.7] | [3.7,5.7] | [17.2,21.0]
| N= 33 | N=23 | N=10 | N=15 | N=12 | N=3
≥ 3 strategies | 0.66 | 0.44 | 1.4 | 5.6 | 5.0 | 21.0
| [0.33, 1. 40] | [0.22,0.68] | [1.33,1.92] | [4.7,16.5] | [4.5,6.0] | [18.0,23.9]
| N=22 | N=14 | N=8 | N=11 | N=9 | N=2
≥ 4 strategies | 0.6 | 0.47 | 1.5 | 4.5 | 2.8 | 18.0
| [0.41,1.1] | [0.3,0.71] | [0.95,2.13] | [2.8,11.3] | [1.0,4.5] | ——
| N=13 | N=9 | N=4 | N=3 | N=2 | N=1
≥ 5 strategies | 0.71 | 0.6 | 1.95 | 1.0 | 1.0 | ——
| [0.53,1.29] | [0.47,0.71] | [1.1,2.8] | —— | ——
| N=7 | N=5 | N=2 | N=1 | N=1 | N=0
6 strategies | 1.09 | 1.09 | —— | —— | —— | ——
| [0.71,1.47] | [0.71,1.47]
| N=2 | N=2 | N=0 | N=0 | N=0 | N=0

### Appendix H References

1 Cagliero E, Levina EV, Nathan DM. Immediate feedback of HbA1c levels improves glycemic control in type 1 and insulin-treated type 2 diabetic patients. Diabetes Care. 1999;22:1785-1789. [pmid: 10546008].
2 Clifford RM, Batty KT, Davis TME, et al. A randomised controlled trial of a pharmaceutical care programme in high-risk diabetic patients in an outpatient clinic. International Journal of Pharmacy Practice. 2002;Vol 10:85-90.
3 Hoskins PL, Fowler PM, Constantino M, Forrest J, Yue DK, Turtle JR. Sharing the care of diabetic patients between hospital and general practitioners: does it work?. Diabet Med. 1993;10:81-86. [pmid: 8435994].
4 Pouwer F, Snoek FJ, van der Ploeg HM, Ader HJ, Heine RJ, IN. Monitoring of psychological well-being in outpatients with diabetes: effects on mood, HbA(1c), and the patient's evaluation of the quality of diabetes care: a randomized controlled trial. Diabetes Care. 2001;24:1929–1935.
5 Stroebel RJ, Scheitel SM, Fitz JS, et al. A randomized trial of three diabetes registry implementation strategies in a community internal medicine practice. Jt Comm J Qual Improv. 2002;28:441-450. [pmid: 12174408].
6 Mazzuca SA, Moorman NH, Wheeler ML, et al. The diabetes education study: a controlled trial of the effects of diabetes patient education. Diabetes Care. 1986;9:1-10. [pmid: 3948638].
7 Hirsch IB, Goldberg HI, Ellsworth A, et al. A multifaceted intervention in support of diabetes treatment guidelines: a controlled trial. Diabetes Res Clin Pract. 2002;58:27-36. [pmid: 12161054].