# Articles excluded at the level of full-text review

## References

1 Selected methods for the management of diabetes mellitus. Ann Intern Med 1983; 99:272–4. Not an evaluation of a QI intervention
2 Impact of policy and procedure changes on hospital days among diabetic nursing-home residents—Colorado. MMWR Morb Mortal Wkly Rep 1984; 33:621–4, 629. Study design did not meet criteria for RCT, CBA, or ITS
3 Private practitioners, public health join forces in unique diabetes program. Urban Health 1985; 14:23–7, 46–8. Not an evaluation of a QI intervention
4 Leads from the MMWR. Improving eye care for persons with diabetes mellitus—Michigan. JAMA 1985; 254:3293–4. Not an evaluation of a QI intervention
5 Community-based exercise intervention—the Zuni Diabetes Project. MMWR Morb Mortal Wkly Rep 1987; 36:661–4. Study design did not meet criteria for RCT, CBA, or ITS
6 Leads from the MMWR. Demonstration to improve care practices for diabetic patients in primary care centers—Florida. JAMA 1987; 257:1580–1. Study design did not meet criteria for RCT, CBA, or ITS
7 Program reimburses pharmacists who counsel patients on glyburide product. Am J Hosp Pharm 1992; 49:2645–6. Not an evaluation of a QI intervention
8 Integrated care for diabetes: clinical, psychosocial, and economic evaluation. Diabetes Integrated Care Evaluation Team. BMJ 1994; 308:1208–12. Other^*^ * Combination of reasons: 1) follow-up < 80%; patients were allowed to change treatment assignment, but there was no ITT; main outcome was HbA1c, but all 4 values (control pre/post, Intervention pre/post) were equal AND the common value of 5.3 is too low, possibly b/c study was conducted before assay standardization. Lastly, borderline QI vs. equivalency study
9 Longitudinal electronic records for diabetic patients. Part II: Clinical aspects. J Clin Comput 1995; 22:1–36. Study design did not meet criteria for RCT, CBA, or ITS/outcomes
10 Longitudinal electronic records for diabetic patients. Part I: Clinical aspects. J Clin Comput 1995; 22:1–88. Study design did not meet criteria for RCT, CBA, or ITS/outcomes
11 National Standards for Diabetes Self-Management Education Programs. Task Force to Revise the National Standards. Diabetes Care 1995; 18:141–3. Not an evaluation of a QI intervention
12 From the Centers for Disease Control and Prevention. Availability of diabetes information on the Internet. JAMA 1997; 278:1565. Not an evaluation of a QI intervention
13 From the Centers for Disease Control and Prevention. National Diabetes Awareness Month—November 1997. JAMA 1997; 278:1564. Not an evaluation of a QI intervention
14 Putting primary care guidelines into practice. Med Manag Netw 1998; 6:1–5. Study design did not meet criteria for RCT, CBA, or ITS
15 Disease management program improves diabetes outcomes, curbs hospital costs, utilization. Health Care Cost Reengineering Rep 1998; 3:42–5. Not an evaluation of a QI intervention
16 Innovative touchscreen-driven solution for diabetics. Health Manag Technol 1999; 20:20–1. Not an evaluation of a QI intervention
17 Pilot study proves CM's effectiveness. Hosp Case Manag 2000; 8:17–9. Study design did not meet criteria for RCT, CBA, or ITS
18 Compliance and combinations. Diabetes Obes Metab 2001; 3:383–4. Not an evaluation of a QI intervention
19 ‘Behavior change’ is centerpiece of new DM approach for diabetics. Dis Manag Advis 2001; 7:118–21, 113. Not an evaluation of a QI intervention
20 Diabetes education program in Bulgaria. Patient Educ Couns 2001; 43:111–4. No eligible outcomes
21 In-house diabetes program delivers on a ‘shoestring’ budget. Dis Manag Advis 2002; 8:181–5, 177. Not an evaluation of a QI intervention
22 The Translating Research Into Action for Diabetes (TRIAD) study: a multicenter study of diabetes in managed care. Diabetes Care 2002; 25:386–9. No eligible outcomes
23 From the Centers for Disease Control and Prevention. Preventive-care practices among persons with diabetes—United States, 1995 and 2001. JAMA 2002; 288:2814–5. Study design did not meet criteria for RCT, CBA, or ITS
24 Incentive program focuses physicians on improving outcomes. Perform Improv Advis 2003; 7:49–54. Study design did not meet criteria for RCT, CBA, or ITS
25 Abourizk NN, O'Connor PJ, Crabtree BF, Schnatz JD. An outpatient model of integrated diabetes treatment and education: functional, metabolic, and knowledge outcomes. Diabetes Educ. 1994;20:416-21. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 7851254].
26 Achtmeyer CE, Payne TH, Anawalt BD. Computer order entry system decreased use of sliding scale insulin regimens. Methods Inf Med. 2002;41:277-81. Excluded topic (hospital care only). [pmid: 12425238].
27 Ackerman SJ. Benefits of preventive programs in eye care are visible on the bottom line. A new nationwide effort to improve eye care for people with diabetes gets backing from a study on the cost-effectiveness of screening for retinopathy. Diabetes Care. 1992;15:580-1. Not an evaluation of a QI intervention. [pmid: 1499485].
28 Adams CE, Biggerstaff N. Reduced resource utilization through standardized outcome-focused care plans. J Nurs Adm. 1995;25:43-50. No eligible outcomes. [pmid: 7472616].
29 Adamson TE, Gullion DS. Assessment of 8 continuing medical education. Diabetes Care. 1986;9:11-16. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3948644].
30 Agurs C, et al. A randomized controlled trial of weight reduction and exercise for diabetes management in African-American subjects. Diabetes Care. 1997;20:1503. Patient education or self-management only. [pmid: 9314625].
31 Albisser AM, Schiffrin A, Schulz M, Tiran J, Leibel BS. Insulin dosage adjustment using manual methods and computer algorithms: a comparative study. Med Biol Eng Comput. 1986;24:577-84. No eligible outcomes. [pmid: 3309493].
32 Albisser AM, Harris RI, Sperlich M, Albisser JB. Getting referrals for diabetes education and self-management training. Diabetes Educ 1999; 25:959–60, 963–4, 966 passim. Study design did not meet criteria for RCT, CBA, or ITS
33 Albisser AM. Clinical studies with home glucose clamping. Ann Endocrinol (Paris). 2001;62:11-8. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11240403].
34 Allanach EJ, Allanach BC. Diabetes teaching follow-up compliance: a quality assurance evaluation. Mil Med. 1984;149:73-5. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 6427660].
35 Ambrosiadou BV, Goulis DG, Pappas C. Clinical evaluation of the DIABETES expert system for decision support by multiple regimen insulin dose adjustment. Comput Methods Programs Biomed. 1996;49:105-15. No eligible outcomes. [pmid: 8646833].
36 Anderson RM, Zimbelman L, Green J, Saunders JT, Pohl S. The development of a competency-based interdisciplinary clinical training program in diabetes. Diabetes Educ 1986:200–3. Not an evaluation of a QI intervention
37 Anderson RM, Funnell MM, Barr PA, Dedrick RF, Davis WK. Learning to empower patients. Results of professional education program for diabetes educators. Diabetes Care. 1991;14:584-90. No eligible outcomes. [pmid: 1914799].
38 Anderson RM, Funnell MM, Butler PM, Arnold MS, Fitzgerald JT, Feste CC. Patient empowerment. Results of a randomized controlled trial. Diabetes Care. 1995;18:943-9. Patient education or self-management only. [pmid: 7555554].
39 Ardron M, MacFarlane IA, Robinson C, van Heyningen C, Calverley PM. Anti-smoking advice for young diabetic smokers: is it a waste of breath?. Diabet Med. 1988;5:667-70. Excluded topic (smoking cessation)/No eligible outcomes. [pmid: 2975552].
40 Arlen D, Harkless L, Frykberg R, Garcia I. Skilled nursing facility units. Preliminary screening of geriatric infections. J Am Podiatr Med Assoc. 1990;80:385-92. Not an evaluation of a QI intervention. [pmid: 2374102].
41 Assal. Patient education as the basis for diabetes care in clinical practice and research. Diabetologia. 1985;283:602-603. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 4054450].
42 Bacon GE, Ladu C, Shein HE, Rucknagel DL. Evaluation of glycosylated hemoglobin in the management of young patients with insulin-dependent diabetes mellitus. J Adolesc Health Care. 1986;7:187-90. Excluded topic (Type 1 diabetes only). [pmid: 3700197].
43 Baker SB, Vallbona C, Pavlik V, et al. A diabetes control program in a public health care setting. Public Health Rep. 1993;108:595-605. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 8210258]. [pmcid: 1403436].
44 Baksi AK, Brand J, Nicholas M, Tavabie A, Cartwright BJ, Waterfield MR. Non-consultant peripheral clinics: a new approach to diabetic care. Health Trends. 1984;16:38-40. Not an evaluation of a QI intervention. [pmid: 10267244].
45 Balas EA, Boren SA, Griffing G. Computerized management of diabetes: a synthesis of controlled trials. Proc AMIA Symp 1998:295–9. Not an evaluation of a QI intervention
46 Balik B, Moynihan PM, Haig B. Community-based diabetes education: an outreach program. Diabetes Educ. 1985;11:19-23. Not an evaluation of a QI intervention. [pmid: 3852727].
47 Barrera M Jr, Glasgow RE, McKay HG, Boles SM, Feil EG. Do Internet-based support interventions change perceptions of social support?: An experimental trial of approaches for supporting diabetes self-management. Am J Community Psychol. 2002;30:637-54. No eligible outcomes. [pmid: 12188054].
48 Bartel J. A comprehensive diabetes education program. Nurs Manage. 1992;23:74-6. Not an evaluation of a QI intervention. [pmid: 1448225].
49 Barth R, Campbell LV, Allen S, Jupp JJ, Chisholm DJ. Intensive education improves knowledge, compliance, and foot problems in type 2 diabetes. Diabet Med. 1991;8:111-7. Patient education or self-management only. [pmid: 1827394].
50 Bashook PG. Clinical assessment: a state-of-the-art review. Diabetes Educ. 1985;11(Suppl):30-6. Not an evaluation of a QI intervention. [pmid: 3853979].
51 Beaven DW, Scott RS, Brown LJ. Diabetes care—a continuing challenge. Aust N Z J Med. 1988;18:297-301. Not an evaluation of a QI intervention. [pmid: 3190583].
52 Beck MJ, Evans BJ, Quarry-Horn JL, Kerrigan JR. Type 2 diabetes mellitus: issues for the medical care of pediatric and adult patients. South Med J. 2002;95:992-1000. Not an evaluation of a QI intervention. [pmid: 12356140].
53 Bell R, Norman M, Lamb B, Holliday J, Leggett-Frazier N. Assessing the effectiveness of a clinical fellowship on diabetes in enhancing diabetes care in North Carolina. Diabetes Educ 2000; 26:41–2, 53–4, 57. No eligible outcomes
54 Bellazzi R, Riva A, Montani S, et al. Application report: preliminary evaluation of the T-IDDM project in Pavia. Stud Health Technol Inform. 1999;68:99-101. Not an evaluation of a QI intervention. [pmid: 10725043].
55 Bender AP, Sprafka JM, Jagger H, Wannamaker J, Muckala KH. Evaluation of the effect of record source on the profiles of patients with diabetes mellitus in Wadena, Minnesota. Minn Med. 1983;66:383-7. Not an evaluation of a QI intervention. [pmid: 6877221].
56 Ben-Noun L. Poorly controlled diabetes in the elderly. Practitioner 1989; 233:14, 16. Not an evaluation of a QI intervention /No eligible outcomes
57 Berger A. Action on clinical audit: progress report 2. BMJ. 1998;317:880-1. Not an evaluation of a QI intervention /No eligible outcomes. [pmid: 9748193]. [pmcid: 1113954].
58 Berkowitz KJ, Anderson LA, Panayioto RM, Ziemer DC, Gallina DL. Mini-residency on diabetes care for healthcare providers: enhanced knowledge and attitudes with unexpected challenges to assessing behavior change. Diabetes Educ 1998; 24:143–4, 149–50. No eligible outcomes
59 Bessman AN. Comparison of medical care in nurse clinician and physician clinics in medical school affiliated hospitals. Journal of Chronic Diseases. 1974;27:115-125. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 4830840].
60 Birke JA, Horswell R, Patout CA Jr, Chen SL. The impact of a staged management approach to diabetes foot care in the Louisiana public hospital system. J La State Med Soc. 2003;155:37-42. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12656273].
61 Blonde L, Guthrie R, Testa M, et al. Diabetes management by a team of diabetes nurse educators, endocrinologists and primary care physicians in a managed care setting [abstract]. Book/Association for Health Services Research; 16:318–319. Other ˆ ˆ Insufficient information; contacted first author - still not available as journal publication or completed manuscript
62 Bloomgarden, et al. Randomized, controlled trial of diabetic patient education: improved knowledge without improved metabolic status. Diabetes Care. 1987;10:263. Patient education or self-management only. [pmid: 3297575].
63 Bloomgarden ZT. International Diabetes Federation meeting, 1997. Neuropathy, information technology, cost of diabetes care, and epidemiology. Diabetes Care. 1998;21:1198-202. Not an evaluation of a QI intervention. [pmid: 9653620].
64 Blum A. Sugar ‘n’ spice— ‘n’ public relations. Med J Aust. 1982;2:16-9. Not an evaluation of a QI intervention. [pmid: 7110012].
65 Bodenheimer T, Wagner EH, Grumbach K. Improving primary care for patients with chronic illness: the chronic care model, Part 2. JAMA. 2002;288:1909-14. Not an evaluation of a QI intervention. [pmid: 12377092].
66 Bodenheimer T, Wagner EH, Grumbach K. Improving primary care for patients with chronic illness. JAMA. 2002;288:1775-9. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12365965].
67 Boehm S, Schlenk EA, Raleigh E, Ronis D. Behavioral analysis and behavioral strategies to improve self-management of type II diabetes. Clin Nurs Res. 1993;2:327-44. Patient education or self-management only. [pmid: 8401245].
68 Bohannon NJ, Zilbergeld B, Bullard DG, Stoklosa JM. Treatable impotence in diabetic patients. West J Med. 1982;136:6-10. Not an evaluation of a QI intervention /No eligible outcomes. [pmid: 7072242]. [pmcid: 1273367].
69 Boswell EJ, Pichert JW, Penha ML. Negotiating independent practice in diabetes education. Diabetes Educ. 1992;18:288-290. Not an evaluation of a QI intervention /No eligible outcomes. [pmid: 1628528].
70 Bowyer NK. A primary care team approach to the prevention of ocular complications of diabetes: a program review. J Am Optom Assoc. 1997;68:233-42. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9150659].
71 Boyd AF, Hartzema AG. Computerized monitoring protocols as a pharmaceutical care practice enhancement: a conceptual illustration using diabetes mellitus. Ann Pharmacother. 1993;27:963-6. Not an evaluation of a QI intervention. [pmid: 8364283].
72 Branger PJ, van 't Hooft A, van der Wouden JC, Duisterhout JS, van Bemmel JH. dup Shared care for diabetes: supporting communication between primary and secondary care. Medinfo 1998; 9 Pt 1:412–6. (Duplication/overlap of included article ^†^ † Branger, P.J., van't Hooft, A., van der Wouden, J.C., Moorman, P.W., van Bemmel, J.H. Shared care for diabetes: supporting communication between primary and secondary care. Int J Med Inf. 1999;53(2–3):133–42. ) Overlaps with or duplicates another article that was included
73 Brooks RJ, Legoretta AP, Silver AL, Fabius RJ, Krakovitz J. Implementing guidelines for eye care of diabetic patients: results from an HMO intervention study. American Journal of Managed Care. 1996;2:365-369. Study design did not meet criteria for RCT, CBA, or ITS.
74 Brouard N, Mounier F, Schaub C. Ocular lesions of diabetic retinopathy: a computer documentation by correspondence factor analysis. Med Inform (Lond). 1981;6:235-7. Not an evaluation of a QI intervention. [pmid: 7341884].
75 Brown SA, Hedges LV. Predicting metabolic control in diabetes: a pilot study using meta-analysis to estimate a linear model. Nurs Res. 1994;43:362-8. Not an evaluation of a QI intervention /No eligible outcomes. [pmid: 7971301].
76 Brown SA, Hanis CL. A community-based, culturally sensitive education and group-support intervention for Mexican Americans with NIDDM: a pilot study of efficacy. Diabetes Educ. 1995;21:203-10. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 7758387].
77 Brown SA, Upchurch S, Anding R, Winter M, Ramirez G. Promoting weight loss in type II diabetes. Diabetes Care. 1996;19:613-24. Not an evaluation of a QI intervention. [pmid: 8725861].
78 Brown SA, Hanis CL. Culturally competent diabetes education for Mexican Americans: the Starr County Study. Diabetes Educ. 1999;25:226-36. (Duplicate/overlap of article #80 from this table) Overlaps with or duplicates another article that was included. [pmid: 10531848].
79 Brown JB, Nichols GA, Glauber HS. Case-control study of 10 years of comprehensive diabetes care. West J Med. 2000;172:85-90. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10693367]. [pmcid: 1070761].
80 Brown SA, Garcia AA, Kouzekanani K, Hanis CL. Culturally competent diabetes self-management education for Mexican Americans: the Starr County border health initiative. Diabetes Care. 2002;25:259-68. Patient education or self-management only. [pmid: 11815493]. [pmcid: 2134805].
81 Bruckner M, Mangan M, Godin S, Pogach L. Project LEAP of New Jersey: lower extremity amputation prevention in persons with type 2 diabetes. Am J Manag Care. 1999;5:609-16. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10537867].
82 Burden ML, Woghiren O, Burden AC. Diabetes in African Caribbean, and Indo-Asian ethnic minority people. J R Coll Physicians Lond. 2000;34:343-6. Not an evaluation of a QI intervention. [pmid: 11005069].
83 Burnett S, Hurwitz B, Davey C, et al. The implementation of prompted retinal screening for diabetic eye disease by accredited optometrists in an inner-city district of North London: a quality of care study. Diabet Med. 1998;15(Suppl 3):S38-43. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9829768].
84 Burton WN, Connerty CM, IN. Worksite-based diabetes disease management program. Disease Management, 5(1):1–8, 2002 Spring.(20 ref) JC CP 2002:1–8. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes
85 Calvo CB, Rubinstein A. Influence of new evidence on prescription patterns. J Am Board Fam Pract. 2002;15:457-62. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 12463291].
86 Campbell LV, Chisholm DJ, Barth R. Evaluation of the benefits of a diabetes education programme. Diabetes Educ. 1984;10(SPEC NO):46-7. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 6564013].
87 Campbell RK. Pharmaceutical services for patients with diabetes. Module 1. Professional and economic impact of diabetes on pharmacy practice. Am Pharm. 1986;NS26(suppl):1-8. Not an evaluation of a QI intervention /No eligible outcomes.
88 Campbell, et al. The relative effectiveness of educational and behavioral instruction programs for patients with NIDDM: a randomized trial. Diabetes Educ. 1996;22:379. Patient education or self-management only. [pmid: 8846745].
89 Campbell TM, Stamm PL, Johnson JR. Improving drug use in a capitated program for the poor. Am J Health Syst Pharm. 1997;54:2449-50. Not an evaluation of a QI intervention. [pmid: 9359950].
90 Campbell R, Pound P, Pope C, et al. Evaluating meta-ethnography: a synthesis of qualitative research on lay experiences of diabetes and diabetes care. Social Science & Medicine. 2003;56:671-684. Not an evaluation of a QI intervention. [pmid: 12560003].
91 Canga N, De Irala J, Vara E, Duaso MJ, Ferrer A, Martinez-Gonzalez MA. Intervention study for smoking cessation in diabetic patients: a randomized controlled trial in both clinical and primary care settings. Diabetes Care. 2000;23:1455-60. Not an evaluation of a QI intervention /No eligible outcomes. [pmid: 11023136].
92 Carlson A, Rosenqvist U. Locally developed plans for quality diabetes care: Worker and consumer participation in the public healthcare system. Health Educ Res. 1990;5:41. Not an evaluation of a QI intervention /No eligible outcomes.
93 Carlson A, Rosenqvist U. Diabetes care organization, process, and patient outcomes: effects of a diabetes control program. Diabetes Educ. 1991;17:42-8. No eligible outcomes. [pmid: 1986903].
94 Carney T, Helliwell C. Effect of structured postgraduate medical education on the care of patients with diabetes. Br J Gen Pract. 1995;45:149-51. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 7772393]. [pmcid: 1239176].
95 Carter IR, Nash C, Ridgway A. On any Saturday—a practical model for diabetes education. J Natl Med Assoc. 2002;94:67-72. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11853048]. [pmcid: 2594137].
96 Cherry JC, Moffatt TP, Rodriguez C, Dryden K. Diabetes disease management program for an indigent population empowered by telemedicine technology. Diabetes Technol Ther. 2002;4:783-91. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12685802].
97 Chicoye L, Roethel CR, Hatch MH, Wesolowski W. Diabetes care management: a managed care approach. Wmj. 1998;97:32-4. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9540446].
98 Chiou ST, Lin HD, Yu NC, et al. An initial assessment of the feasibility and effectiveness of implementing diabetes shared care system in Taiwan—some experiences from I-Lan County. Diabetes Res Clin Pract. 2001;54(Suppl 1):S67-73. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11580971].
99 Clancy DE, Cope DW, Magruder KM, et al. Evaluating group visits in an uninsured or inadequately insured patient population with uncontrolled type 2 diabetes. Diabetes Educator. 2003;29:292-302. No eligible outcomes. [pmid: 12728756].
100 Clark CM Jr, Chin MH, Davis SN, et al. Incorporating the results of diabetes research into clinical practice: celebrating 25 years of diabetes research and training center translation research. Diabetes Care. 2001;24:2134-42. Not an evaluation of a QI intervention. [pmid: 11723096].
101 Clark CM Jr, Snyder JW, Meek RL, Stutz LM, Parkin CG. A systematic approach to risk stratification and intervention within a managed care environment improves diabetes outcomes and patient satisfaction. Diabetes Care. 2001;24:1079-86. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11375374].
102 Clarke J, Crawford A, Nash DB. Evaluation of a Comprehensive Diabetes Disease Management Program: Progress in the Stuggle for Sustained Behavior Change. Disease Management. 2002;5:77. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes.
103 Coid DR, Duncan C, Carmichael C, McLeod J, Campbell IW. Evaluation of a Fife ‘Novopen’ clinic held within a diabetes patient education centre. Health Bull (Edinb). 1990;48:243-8. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 2243019].
104 Constance A, Crawford K, Hare J, et al. MDON: a network of community partnerships. Fam Community Health. 2002;25:52-60. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12802142].
105 Cook S, Cohen RM. Evaluating a workshop model for improving diabetes patient education programs: is it really successful?. Diabetes Educ. 1986;12:48-50. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3633811].
106 Cook GB. A computer program for teaching and auditing patients' knowledge of diabetes. Diabetes Educ. 1987;13:306-8. Not an evaluation of a QI intervention. [pmid: 3311671].
107 Cook CB, Ziemer DC, El-Kebbi IM, et al. Diabetes in urban African-Americans. XVI. Overcoming clinical inertia improves glycemic control in patients with type 2 diabetes. Diabetes Care. 1999;22:1494-500. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10480515].
108 Cooper HC, Booth K, Gill G, IN. Patients' perspectives on diabetes health care education. Health Education Research 2003; 18:191–206. Patient education or self-management only
109 Corbett CF, IN. A randomized pilot study of improving foot care in home health patients with diabetes. Diabetes Educator. 2003; 29:273–282. Patient education or self-management only
110 Corkery, et al. Effect of a bicultural community health worker on completion of diabetes education in a Hispanic population. Diabetes Care. 1997;20:254. Patient education or self-management only. [pmid: 9051367].
111 Courtney L, Gordon M, Romer L. A clinical path for adult diabetes. Diabetes Educ. 1997;23:664-71. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9416030].
112 Crane M, Werber B. Critical pathway approach to diabetic pedal infections in a multidisciplinary setting. J Foot Ankle Surg. 1999;38:30-3. discussion 82–3. Excluded topic (in-patient care only). [pmid: 10028467].
113 Cranor CW, Bunting BA, Christensen DB. The Asheville Project: long-term clinical and economic outcomes of a community pharmacy diabetes care program. J Am Pharm Assoc (Wash). 2003;43:173-4. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12688435].
114 Cranor CW, Christensen DB. The Asheville Project: factors associated with outcomes of a community pharmacy diabetes care program. J Am Pharm Assoc (Wash). 2003;43:160-72. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12688434].
115 Cranor CW, Christensen DB. The Asheville Project: short-term outcomes of a community pharmacy diabetes care program. J Am Pharm Assoc (Wash). 2003;43:149-59. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12688433].
116 Crawford MJ, Rutter D, Manley C, et al. Systematic review of involving patients in the planning and development of health care. BMJ. 2002;325:1263. design. [pmid: 12458240]. [pmcid: 136920].
117 Cretin S, Farley DO, Dolter KJ, Nicholas W. Evaluating an integrated approach to clinical quality improvement: clinical guidelines, quality measurement, and supportive system design. Med Care. 2001;39:II70-84. Excluded topic (unrelated to diabetes)/No eligible outcomes. [pmid: 11583123].
118 Cummings DM, Morrissey S, Barondes MJ, Rogers L, Gustke S. Screening for diabetic retinopathy in rural areas: the potential of telemedicine. J Rural Health. 2001;17:25-31. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 11354719].
119 Czech MS. A mastery learning program for self blood glucose monitoring. Diabetes Educ. 1984;10:27-30. Not an evaluation of a QI intervention. [pmid: 6370639].
120 Dally DL, Dahar W, Scott A, Roblin D, Khoury AT. The impact of a health education program targeting patients with high visit rates in a managed care organization. Am J Health Promot. 2002;17:101-11. No eligible outcomes. [pmid: 12471862].
121 Daniel M, Green LW, Marion SA, et al. Effectiveness of community-directed diabetes prevention and control in a rural Aboriginal population in British Columbia, Canada. Soc Sci Med. 1999;48:815-32. Patient education or self-management only. [pmid: 10190643].
122 Dans PE, King TM. An office of medical practice evaluation: what is it and why have one?. QRB Qual Rev Bull. 1986;12:320-5. Not an evaluation of a QI intervention. [pmid: 3095763].
123 Davidson JK, Delcher HK, Englund A. Spin-off cost/benefits of expanded nutritional care. Journal of the American Dietetic Association. 1979;75:250-257. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 112138].
124 Davidson MB, Morgan R, Bales B, Pearce MA, Crane M, Graham B. The establishment of a reimbursable diabetes education program. Diabetes Educ 1982; 8:31–3, 38. Study design did not meet criteria for RCT, CBA, or ITS
125 Davidson. The impact of managed care on the care of diabetes patients. Diabetes Spectrum. 1996;9:169-90. Not an evaluation of a QI intervention.
126 Davis ED, Beckman JS, Harris NL, Howe JD, Steele RM. Implementing a nursing care quality program to improve diabetes patient education. J Nurs Care Qual. 1992;6:67-77. No eligible outcomes. [pmid: 1550950].
127 Day JL, Humphreys H, Alban-Davies H. Problems of comprehensive shared diabetes care. Br Med J (Clin Res Ed). 1987;294:1590-2. Study design did not meet criteria for RCT, CBA, or ITS.
128 Day JL, Johnson P, Rayman G, Walker R. The feasibility of a potentially ‘ideal’ system of integrated diabetes care and education based on a day centre. Diabet Med. 1988;5:70-5. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 2964332].
129 Day JL, Metcalfe J, Johnson P. Benefits provided by an integrated education and clinical diabetes centre: a follow-up study. Diabet Med. 1992;9:855-9. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 1473327].
130 de Grauw WJ, van Gerwen WH, van de Lisdonk EH, van den Hoogen HJ, van den Bosch WJ, van Weel C. Outcomes of audit-enhanced monitoring of patients with type 2 diabetes. J Fam Pract. 2002;51:459-64. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12019056].
131 de Weerdt I, Visser AP, Kok GJ, de Weerdt O, van der Veen EA. Randomized controlled multicentre evaluation of an education programme for insulin-treated diabetic patients: effects on metabolic control, quality of life, and costs of therapy. Diabet Med. 1991;8:338-45. Patient education or self-management only. [pmid: 1830257].
132 Deichmann RE, Castello E, Horswell R, Friday KE. Improvements in diabetic care as measured by HbA1c after a physician education project. Diabetes Care. 1999;22:1612-6. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10526723].
133 D'Eramo-Melkus GA, Wylie-Rosett J, Hagan JA. Metabolic impact of education in NIDDM. Diabetes Care. 1992;15:864-9. Patient education or self-management only. [pmid: 1516506].
134 Diehl AK, Sugarek NJ, Bauer RL. Medication compliance in non-insulin-dependent diabetes: a randomized comparison of chlorpropamide and insulin. Diabetes Care. 1985;8:219-23. Not an evaluation of a QI intervention. [pmid: 3891264].
135 Dimmick SL, Burgiss SG, Robbins S, Black D, Jarnagin B, Anders M. Outcomes of an integrated telehealth network demonstration project. Telemed J E Health. 2003;9:13-23. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12699604].
136 Domenech MI, Assad D, Mazzei ME, Kronsbein P, Gagliardino JJ. Evaluation of the effectiveness of an ambulatory teaching/treatment programme for non-insulin dependent (type 2) diabetic patients. Acta Diabetol. 1995;32:143-7. Patient education or self-management only. [pmid: 8590781].
137 Domurat ES. Diabetes managed care and clinical outcomes: the Harbor City, California Kaiser Permanente diabetes care system. Am J Manag Care. 1999;5:1299-307. Not an evaluation of a QI intervention. [pmid: 10622995].
138 Donohoe ME, Fletton JA, Hook A, et al. Improving foot care for people with diabetes mellitus—a randomized controlled trial of an integrated care approach. Diabet Med. 2000;17:581-7. No eligible outcomes. [pmid: 11073179].
139 Dornan C, Fowler G, Mann JI, Markus A, Thorogood M. A community study of diabetes in Oxfordshire. J R Coll Gen Pract. 1983;33:151-5. Not an evaluation of a QI intervention. [pmid: 6842436]. [pmcid: 1972741].
140 Drapin L. I/S component crucial to diabetes management program. Health Manag Technol 1995; 16:30, 32. Not an evaluation of a QI intervention
141 Dunn SM, Beeney LJ, Hoskins PL, Turtle JR. Knowledge and attitude change as predictors of metabolic improvement in diabetes education. Soc Sci Med. 1990;31:1135-41. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 2274802].
142 Eakin EG, Bull SS, Glasgow RE, Mason M. Reaching those most in need: a review of diabetes self-management interventions in disadvantaged populations. Diabetes Metab Res Rev. 2002;18:26-35. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11921415].
143 Edmonds. Improved survival of the diabetic foot: the role of the specialised foot clinic. QJ Med. 1986;60:763. Study design did not meet criteria for RCT, CBA, or ITS.
144 Edmonds M, Bauer M, Osborn S, et al. Using the Vista 350 telephone to communicate the results of home monitoring of diabetes mellitus to a central database and to provide feedback. Int J Med Inf. 1998;51:117-25. Excluded topic (Type 1 diabetes only)/No eligible outcomes.
145 Engelman KK, Ellerbeck EF, Totten B. Improving systems for preventive care via academic detailing by students. Acad Med. 2001;76:565-6. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11346620].
146 Erdman DM, Cook CB, Greenlund KJ, et al. The impact of outpatient diabetes management on serum lipids in urban African-Americans with type 2 diabetes. Diabetes Care. 2002;25:9-15. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11772894].
147 Estey AL, Tan MH, Mann K. Follow-up intervention: its effect on compliance behavior to a diabetes regimen. Diabetes Educ. 1990;16:291-5. Patient education or self-management only. [pmid: 2357919].
148 Falkenberg, et al. Problem oriented participatory education in the guidance of adults with non-insulin-treated type-II diabetes mellitus. Scand J Prim Health Care. 1986;4:157. Patient education or self-management only. [pmid: 3775139].
149 Felig P, Bergman M. Intensive ambulatory treatment of insulin-dependent diabetes. Ann Intern Med. 1982;97:225-30. Not an evaluation of a QI intervention. [pmid: 7049031].
150 Fernando DJ, Perera SD. The work of a diabetes clinic: an audit. Ceylon Med J. 1994;39:138-9. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 7820894].
151 Filippi A, Sabatini A, Badioli L, et al. Effects of an Automated Electronic Reminder in Changing the Antiplatelet Drug-Prescribing Behavior Among Italian General Practitioners in Diabetic Patients: An intervention trial. Diabetes Care. 2003;26:1497-500. No eligible outcomes. [pmid: 12716811].
152 Fox CH, Mahoney MC. Improving diabetes preventive care in a family practice residency program: a case study in continuous quality improvement. Fam Med. 1998;30:441-5. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9624524].
153 Frame. Computer based vs manual health maintenence tracking: a controlled trial. Arch Fam Med. 1994;3:581. Excluded topic (unrelated to diabetes)/No eligible outcomes. [pmid: 7921293].
154 Franz MJ, Splett PL, Monk A, et al. Cost-effectiveness of medical nutrition therapy provided by dietitians for persons with non-insulin-dependent diabetes mellitus [see comments]. Journal of the American Dietetic Association. 1995;95:1018-1024. (Duplicate/overlap of included article ^§^ § Franz, M.J., Monk, A., Barry, B., et al. Effectiveness of medical nutrition therapy provided by dietitians in the management of non-insulin-dependent diabetes mellitus: a randomized, controlled clinical trial. Journal of the American Dietetic Association. 1995;95(9):1009–1017. ) Overlaps with or duplicates another article that was included. [pmid: 7657903].
155 Friedman N. Diabetes and managed care: the Lovelace Health System's Episode of Care Program. Manag Care Q. 1996;4:43-9. Not an evaluation of a QI intervention. [pmid: 10154065].
156 Friedman NM, Gleeson JM, Kent MJ, Foris M, Rodriguez DJ, Cypress M. Management of diabetes mellitus in the Lovelace Health Systems' EPISODES OF CARE program. Eff Clin Pract. 1998;1:5-11. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10345262].
157 Friedman RH. Automated telephone conversations to assess health behavior and deliver behavioral interventions. J Med Syst. 1998;22:95-102. Not an evaluation of a QI intervention /No eligible outcomes. [pmid: 9571516].
158 Friedrich MJ. Enhancing diabetes care in a low-income, high-risk population. JAMA. 2000;283:467-8. Not an evaluation of a QI intervention. [pmid: 10659861].
159 Funnell MM, Arnold MS, Fogler J, Merritt JH, Anderson LA. Participation in a diabetes education and care program: experience from the diabetes care for older adults project. Diabetes Educ. 1998;24:163-7. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 9555354].
160 Fuqua L. Marketing and diabetes education: “a harmonious chorus”. Diabetes Educ. 1989;15:210-3. Not an evaluation of a QI intervention. [pmid: 2714188].
161 Gaede P, Vedel P, Parving HH, Pedersen O. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353:617-22. (Duplicate/overlap of included article^**^ ** Gaede, P., Vedel, P., Larsen, N., Jensen, G.V., Parving, H.H., Pedersen, O. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. 2003;348(5):383–93. ) Overlaps with or duplicates another article that was included. [pmid: 10030326].
162 Gagliardino JJ, Etchegoyen G. A model educational program for people with type 2 diabetes: a cooperative Latin American implementation study (PEDNID-LA). Diabetes Care. 2001;24:1001-7. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11375360].
163 Gary TL, Genkinger JM, Guallar E, Peyrot M, Brancati FL. Meta-analysis of randomized educational behavioral interventions in type 2 diabetes. Diabetes Educ. 2003;29:488-501. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12854339].
164 Gegick CG, Altheimer MD, Kissling GE. Benefits of computerized outcome analysis in diabetes management. Endocr Pract. 2000;6:253-9. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11421541].
165 Genev NM, McGill M, Hoskins PL, et al. Continuing diabetes education by telephone. Diabet Med. 1990;7:920-1. No eligible outcomes. [pmid: 2149691].
166 Gerstein HC, Reddy SS, Dawson KG, Yale JF, Shannon S, Norman G. A controlled evaluation of a national continuing medical education programme designed to improve family physicians' implementation of diabetes-specific clinical practice guidelines. Diabet Med. 1999;16:964-9. No eligible outcomes. [pmid: 10588528].
167 Ghosh S, Aronow WS. Utilization of lipid-lowering drugs in elderly persons with increased serum low-density lipoprotein cholesterol associated with coronary artery disease, symptomatic peripheral arterial disease, prior stroke, or diabetes mellitus before and after an educational program on dyslipidemia treatment. J Gerontol A Biol Sci Med Sci. 2003;58:M432-5. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12730252].
168 Gibbins RL, Saunders J. Develop diabetic care in general practice. BMJ. 1988;297:187-9. Not an evaluation of a QI intervention. [pmid: 3408960]. [pmcid: 1834253].
169 Gilden, et al. Diabetes support groups improve health care of older diabetic patients. J Am Geriatr Soc. 1992;40:147. Patient education or self-management only. [pmid: 1740599].
170 Gilliland SS, Azen SP, Perez GE, Carter JS. Strong in body and spirit: lifestyle intervention for Native American adults with diabetes in New Mexico. Diabetes Care. 2002;25:78-83. Patient education or self-management only. [pmid: 11772905].
171 Ginsberg BH, Tan MH, Mazze R, Bergelson A. Staged diabetes management: computerizing a disease state management program. J Med Syst. 1998;22:77-87. Not an evaluation of a QI intervention. [pmid: 9571514].
172 Glasgow RE, Toobert DJ, Hampson SE, Brown JE, Lewinsohn PM, Donnelly J. Improving self-care among older patients with type II diabetes: the “Sixty Something...” Study. Patient Educ Couns. 1992;19:61-74. Patient education or self-management only. [pmid: 1298950].
173 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38:1062-73. (Duplicate/overlap of article #174 from this table) Overlaps with or duplicates another article that was included. [pmid: 11078048].
174 Glasgow RE, Toobert DJ, Hampson SE, Strycker LA. Implementation, generalization and long-term results of the “choosing well” diabetes self-management intervention. Patient Educ Couns. 2002;48:115-22. Patient education or self-management only. [pmid: 12401414].
175 Glasgow RE, Funnell MM, Bonomi AE, Davis C, Beckham V, Wagner EH. Self-management aspects of the improving chronic illness care breakthrough series: implementation with diabetes and heart failure teams. Ann Behav Med. 2002;24:80-7. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12054323].
176 Gleeson. Diabetes mellitus: disease management in a multispecialty group practice. Dis Manag Health Outcomes. 1999;5:63. Not an evaluation of a QI intervention.
177 Goldberg HI, Neighbor WE, Hirsch IB, Cheadle AD, Ramsey SD, Gore E. Evidence-based management: using serial firm trials to improve diabetes care quality. Jt Comm J Qual Improv. 2002;28:155-66. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11942259].
178 Goldhaber-Fiebert JD, Goldhaber-Fiebert SN, Tristan ML, Nathan DM. Randomized controlled community-based nutrition and exercise intervention improves glycemia and cardiovascular risk factors in type 2 diabetic patients in rural Costa Rica. Diabetes Care. 2003;26:24-9. Patient education or self-management only. [pmid: 12502654].
179 Gomez EJ, Hernando ME, Garcia A, et al. Telemedicine as a tool for intensive management of diabetes: the DIABTel experience. Comput Methods Programs Biomed. 2002;69:163-77. Excluded topic (Type 1 diabetes only). [pmid: 12100795].
180 Goodman RM, Liburd LC, Green-Phillips A. The formation of a complex community program for diabetes control: lessons learned from a case study of Project DIRECT. J Public Health Manag Pract. 2001;7:19-29. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11338083].
181 Goyder EC, McNally PG, Drucquer M, Spiers N, Botha JL. Shifting of care for diabetes from secondary to primary care, 1990-5: review of general practices. BMJ. 1998;316:1505-6. Not an evaluation of a QI intervention. [pmid: 9582142]. [pmcid: 28554].
182 Graber AL, Elasy TA, Quinn D, Wolff K, Brown A. Improving glycemic control in adults with diabetes mellitus: shared responsibility in primary care practices. South Med J. 2002;95:684-90. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12144072].
183 Grabert M, Schweiggert F, Holl RW. A framework for diabetes documentation and quality management in Germany: 10 years of experience with DPV. Comput Methods Programs Biomed. 2002;69:115-21. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 12100791].
184 Greenfield S, Kaplan SH, Ware JE Jr, Yano EM, Frank HJ. Patients' participation in medical care: effects on blood sugar control and quality of life in diabetes. J Gen Intern Med. 1988;3:448-57. Patient education or self-management only. [pmid: 3049968].
185 Greenhalgh PM. Shared care for diabetes. A systematic review. Occas Pap R Coll Gen Pract 1994:i–viii, 1–35. Study design did not meet criteria for RCT, CBA, or ITS
186 Grey N, Maljanian R, Staff I, Cruzmarino de Aponte M. Improving care of diabetic patients through a collaborative care model. Conn Med. 2002;66:7-11. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11852739].
187 Grieve R, Beech R, Vincent J, Mazurkiewicz J. Near patient testing in diabetes clinics: appraising the costs and outcomes. Health Technol Assess. 1999;3:1-74. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10632625].
188 Griffin S. Diabetes care in general practice: meta-analysis of randomised control trials. BMJ. 1998;317:390-6. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9694757]. [pmcid: 28634].
189 Griffin S, Kinmonth AL. Diabetes care: the effectiveness of systems for routine surveillance for people with diabetes. Cochrane Database Syst Rev 2000:CD000541. Not an evaluation of a QI intervention
190 Gruesser M, Hartmann P, Schlottmann N, Joergens V. Structured treatment and teaching programme for type 2 diabetic patients on conventional insulin treatment: evaluation of reimbursement policy. Patient Educ Couns. 1996;29:123-30. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9006229].
191 Grundel BL, White GL Jr, Eichold BH 2nd. Diabetes in the managed care setting: a prospective plan. South Med J. 1999;92:459-64. Not an evaluation of a QI intervention. [pmid: 10342889].
192 Halbert RJ, Leung KM, Nichol JM, Legorreta AP. Effect of multiple patient reminders in improving diabetic retinopathy screening. A randomized trial. Diabetes Care. 1999;22:752-5. Patient education or self-management only. [pmid: 10332676].
193 Hanefeld M, Fischer S, Schmechel H, et al. Diabetes Intervention Study. Multi-intervention trial in newly diagnosed NIDDM. Diabetes Care. 1991;14:308-17. Patient education or self-management only. [pmid: 2060433].
194 Haring OM. Improving Patient Care by Automated Record Summaries. Final rept. 15 Jun 72–31 May 76,. 1976.May 31 1976; 60 p. NTIS Order Number:B-267. Publication prior to 1980
195 Harrower. Improvement in psychological well-being in new NIDDMs. DSNVs medical initial assessment. Pract Diab Int. 1995;12:120. No eligible outcomes.
196 Hart JT. Community general practitioners. Br Med J (Clin Res Ed). 1984;288:1670-3. Not an evaluation of a QI intervention.
197 Harwell TS, McDowall JM, Gohdes D, Helgerson SD. Measuring and improving preventive care for patients with diabetes in primary health centers. Am J Med Qual. 2002;17:179-84. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12412945].
198 Hawkins, et al. Evaluation of a clinical pharmacist in caring for hypertensive and diabetic patients. American Journal of Hospital Pharmacy. 1979;36:1321. Not an evaluation of a QI intervention. [pmid: 507073].
199 Hawkins DW. Clinical pharmacy functions in ambulatory patient care. J Clin Pharmacol. 1981;21:245-50. Not an evaluation of a QI intervention. [pmid: 7021606].
200 Hawthorne K, Tomlinson S. One-to-one teaching with pictures - flashcard health education for British Asians with diabetes. Br J Gen Pract. 1997;47:301. Patient education or self-management only. [pmid: 9219407]. [pmcid: 1313005].
201 Heath GW, Leonard BE, Wilson RH, Kendrick JS, Powell KE. Community-based exercise intervention: Zuni Diabetes Project. Diabetes Care. 1987;10:579-83. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3677975].
202 Heatlie JM. Reducing insulin medication errors: evaluation of a quality improvement initiative. J Nurses Staff Dev. 2003;19:92-8. Study design did not meet criteria for RCT, CBA, or ITS/Excluded topic (hospital care only). [pmid: 12679661].
203 Heller, et al. Group education for obese patients with type 2 diabetes: greater success at less cost. Diabet Med. 1988;5:552. Patient education or self-management only. [pmid: 2974778].
204 Heller S, MacKinnon M. Education health professionals. Diabetes Rev Int. 1998;7:16-18. Not an evaluation of a QI intervention.
205 Hendricks LE, Hendricks RT. The effect of diabetes self-management education with frequent follow-up on the health outcomes of African American men. Diabetes Educ. 2000;26:995-1002. Patient education or self-management only. [pmid: 11912812].
206 Hidaka H, Terada M, Maegawa H, et al. Evaluation of a new care system provided to diabetic patients in the outpatient clinic. Intern Med. 2000;39:783-7. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11030200].
207 Hilton RA. Does diabetic control really make a difference?. Can Nurse. 1982;78:49-52. Not an evaluation of a QI intervention. [pmid: 6922735].
208 Hiss RG, Gillard ML, Armbruster BA, McClure LA. Comprehensive evaluation of community-based diabetic patients: effect of feedback to patients and their physicians: a randomized controlled trial. Diabetes Care. 2001;24:690-4. Patient education or self-management only. [pmid: 11315832].
209 Hood FJ. Diabetes coding. South Med J. 2002;95:64-6. Not an evaluation of a QI intervention. [pmid: 11827246].
210 Hoppener P, Knottnerus JA, Grol R, Metsemakers JF. Computerization of general practices and quality control. Blood glucose regulation in type 2 diabetics investigated in the Registration Network family practices. Fam Pract. 1992;9:353-6. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 1459394].
211 Hopper SV, Miller JP, Birge C, Swift J. A randomized study of the impact of home health aides on diabetic control and utilization patterns. Am J Public Health. 1984;74:600-2. Patient education or self-management only. [pmid: 6721016]. [pmcid: 1651641].
212 Hoskings PH, Alford J, Fowler P, et al. Outpatient stabilisation program. An innovative approach in the management of diabetes in a large teaching hospital. Aust Clin Rev 1984:8–11. Study design did not meet criteria for RCT, CBA, or ITS
213 Hoskins PL, Alford JB, Handelsman DJ, Yue DK, Turtle JR. Comparison of different models of diabetes care on compliance with self-monitoring of blood glucose by memory glucometer. Diabetes Care. 1988;11:719-24. No eligible outcomes. [pmid: 3224543].
214 Hosler AS, Godley K, Rowland DH. An initiative to improve diabetes care standards in healthcare organizations serving minorities. Diabetes Educ. 2002;28:581-9. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 12224198].
215 Howorka K, Pumprla J, Wagner-Nosiska D, Grillmayr H, Schlusche C, Schabmann A. Empowering diabetes out-patients with structured education: short-term and long-term effects of functional insulin treatment on perceived control over diabetes. J Psychosom Res. 2000;48:37-44. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 10750628].
216 Hull M. How to set up a diabetes education program. Rn. 1989;52:61-4. Not an evaluation of a QI intervention. [pmid: 2587921].
217 Humphry J, Jameson LM, Beckham S. Overcoming social and cultural barriers to care for patients with diabetes. West J Med. 1997;167:138-44. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9308405]. [pmcid: 1304512].
218 Hunt DL, Haynes RB, Hanna SE, Smith K. Effects of computer-based clinical decision support systems on physician performance and patient outcomes: a systematic review. JAMA. 1998;280:1339-46. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9794315].
219 Ibrahim IA, Beich J, Sidorov J, Gabbay R, Yu L. Measuring outcomes of type 2 diabetes disease management program in an HMO setting. South Med J. 2002;95:78-87. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11827249].
220 Ivey JM, Ehle J. Establishing unit-based glucose monitoring. Diabetes Educ. 1988;14:487-91. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3208636].
221 Izquierdo PEKSMJKRP-S, Weinstock RS. A comparison of diabetes education administered through telemedicine versus in person. Diabetes Care. 2003;26:1002-7. Patient education or self-management only. [pmid: 12663564].
222 Jacobs M, Feit J. Healthy lifestyles: a pilot program to influence behavior change. Diabetes Educ 2000; 26:230–2, 234, 240 passim. Study design did not meet criteria for RCT, CBA, or ITS
223 Jacobson JM, O'Rourke PJ, Wolf AE, IN. Impact of a diabetes teaching program on health care trends in an Air Force Medical Center. Military Medicine 1983; 148:46–47. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes
224 Jarrett J, Stewart T, Rogers L. Diabetes mellitus. III: Complications and organising long-term management. Br Med J (Clin Res Ed). 1981;283:763-5. Not an evaluation of a QI intervention.
225 Joergens V, Gruesser M. Three years' experience after national introduction of teaching programs for type II diabetic patients in Germany: how to train general practitioners. Patient Educ Couns. 1995;26:195-202. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 7494722].
226 Johnson NE, Nash DB. Key factors in the implementation of a clinical quality improvement project: successes and challenges. Am J Med Qual. 1993;8:118-22. Not an evaluation of a QI intervention. [pmid: 8219872].
227 Johnson EQ, Valera S. Medical nutrition therapy in non-insulin-dependent diabetes mellitus improves clinical outcome. J Am Diet Assoc. 1995;95:700-1. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 7759749].
228 Jones PM. Use of a course on self-control behavior techniques to increase adherence to prescribed frequency for self-monitoring blood glucose. Diabetes Educ. 1990;16:296-303. No eligible outcomes. [pmid: 2357920].
229 Jones PC, Silverman BG, Athanasoulis M, et al. Nationwide telecare for diabetics: a pilot implementation of the HOLON architecture. Proc AMIA Symp 1998:346–50. Not an evaluation of a QI intervention
230 Jones PM. Quality improvement initiative to integrate teaching diabetes standards into home care visits. Diabetes Educ. 2002;28:1009-20. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12526641].
231 Jovanovic L, Peterson CM. Toward normoglycemia: studies in computer-assisted insulin delivery. Diabetes Educ. 1987;13:302-5. Study design did not meet criteria for RCT, CBA, or ITS/Excluded topic (Type 1 diabetes only). [pmid: 3311670].
232 Joyner L, McNeeley S, Kahn R. ADA's (American Diabetes Association) provider recognition program. HMO Pract. 1997;11:168-70. Not an evaluation of a QI intervention. [pmid: 10176518].
233 Kalten MR, Ardito DA, Cimino C, Wylie-Rosett J. A Web-accessible core weight management program. Diabetes Educ. 2000;26:929-36. No eligible outcomes. [pmid: 11912805].
234 Kaplan RM, Wilson DK, Hartwell SL, Merino KL, Wallace JP. Prospective evaluation of HDL cholesterol changes after diet and physical conditioning programs for patients with type II diabetes mellitus. Diabetes Care. 1985;8:343-8. No eligible outcomes. [pmid: 4042800].
235 Kaplan SH, Greenfield S, Ware JE Jr. Assessing the effects of physician-patient interactions on the outcomes of chronic disease [published erratum appears in Med Care 1989 Jul;27(7):679]. Medical Care. 1989;27:S110-S127. Not an evaluation of a QI intervention /No eligible outcomes. [pmid: 2646486].
236 Karlander SG, Kindstedt K. Effects of a formalized diabetes education. Acta Med Scand. 1983;213:41-3. Patient education or self-management only. [pmid: 6829317].
237 Kay S. A standard architecture for sustainability and integration of care. Diabetes Nutr Metab. 2001;14:89-92. Not an evaluation of a QI intervention. [pmid: 11383680].
238 Kelling DG, Wentworth JA, Wright JB. Diabetes mellitus. Using a database to implement a systematic management program. N C Med J. 1997;58:368-71. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9313362].
239 Kendall PA, Jansen CM, Sjogren DD, Jansen GR. A comparison of nutrient-based and exchange-group methods of diet instruction for patients with noninsulin-dependent diabetes. Am J Clin Nutr. 1987;45:625-37. Not an evaluation of a QI intervention. [pmid: 3825986].
240 Kendall D, Lunt H, Moore MP, McSweeney WP. Diabetes complication screening in general practice: a two pass audit with benchmarking. N Z Med J. 1999;112:141-4. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10340694].
241 Kerr D, Haigh R. Intensive diabetes treatment: a new deal for old people?. Age Ageing. 1994;23:89-90. Not an evaluation of a QI intervention. [pmid: 8023734].
242 Khunti K, Baker R, Ganguli S. Clinical governance for diabetes in primary care: use of practice guidelines and participation in multi-practice audit. Br J Gen Pract. 2000;50:877-81. Not an evaluation of a QI intervention /No eligible outcomes. [pmid: 11141873]. [pmcid: 1313851].
243 Kiechle FL. The impact of continuous glucose monitoring on hospital point-of-care testing programs. Diabetes Technol Ther. 2001;3:647-50. Not an evaluation of a QI intervention. [pmid: 11911179].
244 Kilo C, Miller JP, Williamson JR. The crux of the UGDP. Spurious results and biologically inappropriate data analysis. Diabetologia. 1980;18:179-85. Not an evaluation of a QI intervention. [pmid: 6989693].
245 Kim J, Philips TL. The effectiveness of two forms of corrective feedback in diabetes education. J computer-based educ. 1991;19:14. No eligible outcomes.
246 Kirk AF, Higgins LA, Hughes AR, et al. A randomized, controlled trial to study the effect of exercise consultation on the promotion of physical activity in people with Type 2 diabetes: a pilot study. Diabet Med. 2001;18:877-82. No eligible outcomes. [pmid: 11703431].
247 Kirkman MS, Weinberger M, Landsman PB, et al. A telephone-delivered intervention for patients with NIDDM. Effect on coronary risk factors. Diabetes Care. 1994;17:840-6. (Duplicate/overlap of included article ˆˆ ˆˆ– ˆ Weinberger, M., Kirkman, M.S., Samsa, G.P., et al. A nurse-coordinated intervention for primary care patients with non-insulin-dependent diabetes mellitus: impact on glycemic control and health-related quality of life. J Gen Intern Med. 1995;10(2):59–66. ) Overlaps with or duplicates another article that was included. [pmid: 7956628].
248 Kirkman MS, Williams SR, Caffrey HH, Marrero DG. Impact of a program to improve adherence to diabetes guidelines by primary care physicians. Diabetes Care. 2002;25:1946-51. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12401737].
249 Kleschen MZ, Holbrook J, Rothbaum AK, Stringer RA, McInerney MJ, Helgerson SD. Improving the pneumococcal immunization rate for patients with diabetes in a managed care population: a simple intervention with a rapid effect. Jt Comm J Qual Improv. 2000;26:538-46. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 10983294].
250 Knopf RF, Kittel PR, Funnell MM, Wolf FM. Development and evaluation of diabetes continuing education courses for health professionals: a synthesis of eight years of experience. Diabetes Educ. 1988;14:136-41. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3349914].
251 Knowles EA, Gem J, Boulton AJ. The diabetic foot and the role of a multidisciplinary clinic. J Wound Care. 1996;5:452-4. Not an evaluation of a QI intervention. [pmid: 9117815].
252 Korhonen T, Huttunen JK, Aro A, et al. A controlled trial on the effects of patient education in the treatment of insulin-dependent diabetes. Diabetes Care. 1983;6:256-61. Excluded topic (Type 1 diabetes only). [pmid: 6347578].
253 Krier BP, Parker RD, Grayson D, Byrd G. Effect of diabetes education on glucose control. J La State Med Soc. 1999;151:86-92. Patient education or self-management only. [pmid: 11280842].
254 Krishna S, Balas EA, Spencer DC, Griffin JZ, Boren SA. Clinical trials of interactive computerized patient education: implications for family practice. J Fam Pract. 1997;45:25-33. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9228910].
255 Kronsbein, et al. Evaluation of a structured treatment and teaching programme on non-insulin dependent diabetes. Lancet. 1988;2:1407. Patient education or self-management only. [pmid: 2904532].
256 Lafata JE, Baker AM, Divine GW, McCarthy BD, Xi H. The use of computerized birthday greeting reminders in the management of diabetes. J Gen Intern Med. 2002;17:521-30. Patient education or self-management only. [pmid: 12133142]. [pmcid: 1495071].
257 Larkin M. Diabetes on the rise worldwide and webwide. Lancet. 2001;357:815. Not an evaluation of a QI intervention. [pmid: 11254014].
258 Laron Z, Faiman G, Flexer Z, Rapaport M. Use of a computer program in the treatment and education of young diabetics. Acta Paediatr Jpn. 1987;29:378-84. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3144866].
259 Larsen ML, Horder M, Mogensen EF. Effect of long-term monitoring of glycosylated hemoglobin levels in insulin-dependent diabetes mellitus. N Engl J Med. 1990;323:1021-5. Excluded topic (Type I diabetes only ^††^ †† Specified patients only as “insulin dependent diabetics,” but average age and duration of disease suggested that patients were all Type I diabetics. ). [pmid: 2215560].
260 Lee SJ, Sicari C, Harper CA, et al. Examination compliance and screening for diabetic retinopathy: a 2-year follow-up study. Clin Experiment Ophthalmol. 2000;28:149-52. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10981784].
261 Lee SJ, McCarty CA, Taylor HR, Keeffe JE. Costs of mobile screening for diabetic retinopathy: a practical framework for rural populations. Aust J Rural Health. 2001;9:186-92. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11488703].
262 Leese GP, Ahmed S, Newton RW, et al. Use of mobile screening unit for diabetic retinopathy in rural and urban areas. BMJ. 1993;306:187-9. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 8443485]. [pmcid: 1676588].
263 Leichter SB, Hernandez C, Harvill C, Rice G. The Kentucky Diabetes Control Program and the feasibility of the pyramidal model for public health intervention in diabetes mellitus. Diabetes Educ. 1988;14:218-22. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3371166].
264 Lenz ER, Mundinger MO, Hopkins SC, Lin SX, Smolowitz JL. Diabetes care processes and outcomes in patients treated by nurse practitioners or physicians. Diabetes Educ. 2002;28:590-8. Not an evaluation of a QI intervention. [pmid: 12224199].
265 Leonard B, Leonard C, Wilson R. Zuni Diabetes Project. Public Health Rep. 1986;101:282-8. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 3086921]. [pmcid: 1477688].
266 Levenson D. Benchmarking project spurs better guideline adherence. Rep Med Guidel Outcomes Res. 2001;12:5-7. Not an evaluation of a QI intervention /Excluded topic (unrelated to diabetes).
267 Lewis D, Nath C. Feasibility of a kiosk-based patient education system in a busy outpatient clinic setting. Diabetes Educ 1997; 23:577–81, 585–6. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes
268 Lo R, Lo B, Wells E, Chard M, Hathaway J. The development and evaluation of a computer-aided diabetes education program. Aust J Adv Nurs. 1996;13:19-27. Patient education or self-management only. [pmid: 8900703].
269 Lobach DF, Hammond WE. Development and evaluation of a Computer-Assisted Management Protocol (CAMP): improved compliance with care guidelines for diabetes mellitus. Proc Annu Symp Comput Appl Med Care 1994:787–91. (Duplicate/overlap of included article ^§§^ §§ Lobach, D.F., Hammond, W.E. Computerized decision support based on a clinical practice guideline improves compliance with care standards. Am J Med. 1997;102(1):89–98. ) Overlaps with or duplicates another article that was included
270 Lorenz RA, Pichert JW, Enns SJ, Hanson SL. Impact of organizational interventions on the delivery of patient education in a diabetes clinic. Patient Educ Couns. 1986;8:115-23. No eligible outcomes. [pmid: 10277393].
271 Lorenz RA. Training health professionals to improve the effectiveness of patient education programs. Diabetes Educ 1986:204–9. Not an evaluation of a QI intervention /No eligible outcomes
272 Lurie N, Ward NB, Shapiro MF, Brook RH. Termination from Medi-Cal—does it affect health?. N Engl J Med. 1984;311:480-4. Not an evaluation of a QI intervention. [pmid: 6379458].
273 Lustman PJ, Griffith LS, Freedland KE, Kissel SS, Clouse RE. Cognitive behavior therapy for depression in type 2 diabetes mellitus. A randomized, controlled trial. Ann Intern Med. 1998;129:613-21. Patient education or self-management only. [pmid: 9786808].
274 Luz C. National campaign yields positive results for patients with diabetes. Healthplan. 2002;43:50-1. Not an evaluation of a QI intervention. [pmid: 12221778].
275 Maislos M, Weisman D, Sherf M. Western Negev Mobile Diabetes Care Program: a model for interdisciplinary diabetes care in a semi-rural setting. Acta Diabetol. 2002;39:49-53. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12043939].
276 Major S, Salti I, Masri A, Van Lerberghe W, Boelaert M, Khogali M. Managing diabetes mellitus in a Lebanese primary care centre. Working towards change. J Med Liban. 1998;46:182-8. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9880983].
277 Malone JM, Snyder M, Anderson G, Bernhard VM, Holloway GA Jr, Bunt TJ. Prevention of amputation by diabetic education. American Journal of Surgery. 1989;158:520-523. Patient education or self-management only. [pmid: 2589581].
278 Mancino JM, Rhia LC, McHattie K. Comparison of type 2 diabetes medical nutrition therapy to practice guidelines in a community health system. J Am Diet Assoc. 2002;102:1129-31. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 12171459].
279 Marrero. Increasing the use of intensified managment of diabetes: an education program for physicians. The Journal of Continuing Education in the Health Professions. 1991;11:283. Study design did not meet criteria for RCT, CBA, or ITS/Excluded topic (Type 1 diabetes only).
280 Marrero DG, Vandagriff JL, Kronz K, et al. Using telecommunication technology to manage children with diabetes: the Computer-Linked Outpatient Clinic (CLOC) Study. Diabetes Educ. 1995;21:313-9. Excluded topic (Children/adolescents only). [pmid: 7621734].
281 Marshall CL, Bluestein M, Briere E, et al. Improving outpatient diabetes management through a collaboration of six competing, capitated Medicare managed care plans. American Journal of Medical Quality. 2000;15:65-71. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10763220].
282 Martin EE. Organising a practice. Problem identification, disease management, and audit. Br Med J (Clin Res Ed). 1982;285:265-6. Study design did not meet criteria for RCT, CBA, or ITS.
283 Martin DA, McNeal B, Kronenfeld JJ, Wheeler FC. The impact of professional education on nursing behavior in the practice setting. J Contin Educ Nurs. 1986;17:40-2. Study design did not meet criteria for RCT, CBA, or ITS/No eligible No eligible outcomes. [pmid: 3081606].
284 Matsuyama JR, Mason BJ, Jue SG. Pharmacists' interventions using an electronic medication-event monitoring device's adherence data versus pill counts. Ann Pharmacother. 1993;27:851-5. No eligible outcomes. [pmid: 8364262].
285 Mazze RS, I. Staged diabetes management. Toward an integrated model of diabetes care. Diabetes Care 1994; 17:66. Study design did not meet criteria for RCT, CBA, or ITS
286 Mazzuca SA, Moorman NH, Wheeler ML, et al. The diabetes education study: a controlled trial of the effects of diabetes patient education. Diabetes Care. 1986;9:1-10. *** *** Article compares usual care versus provider education only, usual care versus patient and provider education, and usual care versus patient education only. Exclusion is of usual care versus patient education only comparison. Patient education or self-management only. [pmid: 3948638].
287 Mazzuca SA, Vinicor F, Cohen SJ, et al. The Diabetes Education Study: a controlled trial of the effects of intensive instruction of internal medicine residents on the management of diabetes mellitus. J Gen Intern Med. 1988;3:1-8. Other ˆˆˆ ˆˆˆ ˆˆ Design makes results unusable, study too old to contact authors for more information. [pmid: 3339482].
288 McCabe CJ, Stevenson RC, Dolan AM. Evaluation of a diabetic foot screening and protection programme. Diabet Med. 1998;15:80-4. Patient education or self-management only. [pmid: 9472868].
289 McCulloch DK, Mitchell RD, Ambler J, Tattersall RB. Influence of imaginative teaching of diet on compliance and metabolic control in insulin dependent diabetes. Br Med J (Clin Res Ed). 1983;287:1858-61. Excluded topic (Type 1 diabetes only).
290 McDonald CJ. Use of a computer to detect and respond to clinical events: its effect on clinician behavior. Annals of Internal Medicine. 1976;84:162-167. Publication prior to 1980. [pmid: 1252043].
291 McDonald CJ, Hui SL, Smith DM, et al. Reminders to physicians from an introspective computer medical record. A two-year randomized trial. Ann Intern Med. 1984;100:130-8. Excluded topic (unrelated to diabetes)/No eligible No eligible outcomes. [pmid: 6691639].
292 McKay HG, King D, Eakin EG, Seeley JR, Glasgow RE. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care. 2001;24:1328-34. No eligible outcomes. [pmid: 11473065].
293 McKenna M, Dolan M, Loughlin T, et al. Evaluation of impact on diabetic control of increased surveillance, and of human and U-100 insulins. Ir J Med Sci. 1987;156:347-52. Excluded topic (Type 1 diabetes only). [pmid: 3325451].
294 McMahon LM, Longabaugh R, Desrosiers M, Kriebel GW Jr. Management of physical problems in a psychiatric hospital: a study of problem-oriented patient care. QRB Qual Rev Bull. 1981;7:13-9. No eligible outcomes. [pmid: 6795561].
295 McNabb WL, Cook S, Fischer B, Quinn MT, Haas L. Dissemination of a continuing education program in diabetes to health care professionals. Diabetes Educ. 1994;20:35-40. Not an evaluation of a QI intervention /No eligible No eligible outcomes. [pmid: 8137702].
296 McNally PG, MacIver DH, Jowett NI, Hearnshaw JR. Hypoglycaemia in insulin dependent diabetics: is advice heeded?. Br Med J (Clin Res Ed). 1987;294:1655-6. Study design did not meet criteria for RCT, CBA, or ITS.
297 Michael P. Impact and components of the Medicare MNT benefit. J Am Diet Assoc. 2001;101:1140-1. Not an evaluation of a QI intervention. [pmid: 11678481].
298 Mitchell. Does primary medical practitioner involvement with a specialist team improve patient outcomes? A systematic review. Br J Gen Pract. 2002;52:934. Study design did not meet criteria for RCT, CBA, or ITS ble outcomes. [pmid: 12434964]. [pmcid: 1314447].
299 Montani S, Bellazzi R, Quaglini S, d'Annunzio G. Meta-analysis of the effect of the use of computer-based systems on the metabolic control of patients with diabetes mellitus. Diabetes Technol Ther. 2001;3:347-56. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11762513].
300 Moore K, Mengel M. Expanding the team: the use of volunteers in a diabetes education program. Diabetes Educ 2002; 28:554–8, 560, 562. Not an evaluation of a QI intervention
301 Morrison N, Dooley J. The Sioux Lookout Diabetes Program: diabetes prevention and management in northwestern Ontario. Int J Circumpolar Health. 1998;57(Suppl 1):364-9. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10093307].
302 Most RS, Gross AM, Davidson PC, Richardson P. The accuracy of glucose monitoring by diabetic individuals in their home setting. Diabetes Educ. 1986;12:24-7. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3633806].
303 Muhlhauser I, Berger M. Diabetes education and insulin therapy: when will they ever learn?. J Intern Med. 1993;233:321-6. Not an evaluation of a QI intervention. [pmid: 8463764].
304 Mulcahy K, Peeples M, Tomky D, Weaver T. National Diabetes Education Outcomes System: application to practice. Diabetes Educ. 2000;26:957-64. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11912808].
305 Mulrow C, Bailey S, Sonksen PH, Slavin B. Evaluation of an Audiovisual Diabetes Education Program: negative results of a randomized trial of patients with non-insulin-dependent diabetes mellitus. J Gen Intern Med. 1987;2:215-9. Patient education or self-management only. [pmid: 2441013].
306 Munro N, Felton A, McIntosh C. Is multidisciplinary learning effective among those caring for people with diabetes?. Diabet Med. 2002;19:799-803. Not an evaluation of a QI intervention. [pmid: 12358864].
307 Narayan KM, Hoskin M, Kozak D, et al. Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. 1998;15:66-72. Excluded topic (normoglycemic patients). [pmid: 9472866].
308 New JP, Hollis S, Campbell F, et al. Measuring clinical performance and outcomes from diabetes information systems: an observational study. Diabetologia. 2000;43:836-43. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10952454].
309 Nilasena DS, Lincoln MJ. A computer-generated reminder system improves physician compliance with diabetes preventive care guidelines. Proc Annu Symp Comput Appl Med Care 1995:640–5. Other ^§§^ ††† Insufficient patient population size information.
310 Nodhturft VL, MacMullen JA. Standardized nursing care plans... the effect of care plans on documentation of diabetic nursing care. Nursing Management (Chicago.) 1982; 13:33–6, 40–2. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes
311 Noel PH, Larme AC, Meyer J, Marsh G, Correa A, Pugh JA. Patient choice in diabetes education curriculum. Nutritional versus standard content for type 2 diabetes. Diabetes Care. 1998;21:896-901. Patient education or self-management only. [pmid: 9614604].
312 Norris SL, Engelgau MM, Narayan KM. Effectiveness of self-management training in type 2 diabetes: a systematic review of randomized controlled trials. Diabetes Care. 2001;24:561-87. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11289485].
313 Norris SL, Lau J, Smith SJ, Schmid CH, Engelgau MM. Self-management education for adults with type 2 diabetes: a meta-analysis of the effect on glycemic control. Diabetes Care. 2002;25:1159-71. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12087014].
314 Norris SL, Nichols PJ, Caspersen CJ, et al. The effectiveness of disease and case management for people with diabetes. A systematic review. Am J Prev Med. 2002;22:15-38. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11985933].
315 Norris SL, Nichols PJ, Caspersen CJ. Increasing diabetes self-management education in comunity settings. A systematic review. Am J Prev Med. 2002;22:39-66. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11985934].
316 O'Connor PJ, Pronk NP, IN. Integrating population health concepts, clinical guidelines, and ambulatory medical systems to improve diabetes care. Journal of Ambulatory.Care Management 1998; 21:67–73. Not an evaluation of a QI intervention
317 Ornstein SM, Garr DR, Jenkins RG, Rust PF, Arnon A. Computer-generated physician and patient reminders. Tools to improve population adherence to selected preventive services. J Fam Pract. 1991;32:82-90. Excluded topic (unrelated to diabetes)/No eligible outcomes. [pmid: 1985140].
318 Orton P. Shared care. Lancet. 1994;344:1413-5. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 7695704].
319 Overland J, Mira M, Yue DK. Differential shared care for diabetes: does it provide the optimal partition between primary and specialist care?. Diabet Med. 2001;18:554-7. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11553184].
320 Oxman AD, Thomson MA, Davis DA, Haynes RB. No magic bullets: a systematic review of 102 trials of interventions to improve professional practice. CMAJ. 1995;153:1423-31. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 7585368]. [pmcid: 1487455].
321 Park JY, Daly JM. Evaluation of diabetes management software. Diabetes Educ 2003; 29:255–62, 267. Not an evaluation of a QI intervention ble outcomes
322 Parker MT, Leggett-Frazier N, Vincent PA, Swanson MS. The impact of an educational program on improving diabetes knowledge and changing behaviors of nurses in long-term care facilities. Diabetes Educ. 1995;21:541-5. No eligible outcomes. [pmid: 8549258].
323 Perry TL, Mann JI, Lewis-Barned NJ, Duncan AW, Waldron MA, Thompson C. Lifestyle intervention in people with insulin-dependent diabetes mellitus (IDDM). Eur J Clin Nutr. 1997;51:757-63. Patient education or self-management only. [pmid: 9368810].
324 Peters A, Rubsamen M, Jacob U, Look D, Scriba PC. Clinical evaluation of decision support system for insulin-dose adjustment in IDDM. Diabetes Care. 1991;14:875-80. Excluded topic (Type 1 diabetes only). [pmid: 1773685].
325 Peters AL. The effect of a diabetes management program on diabetes health care outcomes in health maintenance organizations. Diabetes 43 suppl 1:84 A 1994.JC CP. 1994;43:84. (Duplicate/overlap of article #327 from this table) Overlaps with or duplicates another article that was included.
326 Peters AL, Davidson MB, Ossorio RC. Management of patients with diabetes by nurses with support of subspecialists. HMO Pract. 1995;9:8-13. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10141351].
327 Peters AL, Davidson MB. Application of a diabetes managed care program. The feasibility of using nurses and a computer system to provide effective care. Diabetes Care. 1998;21:1037-43. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9653591].
328 Petitti DB, Contreras R, Ziel FH, Dudl J, Domurat ES, Hyatt JA. Evaluation of the effect of performance monitoring and feedback on care process, utilization, and outcome. Diabetes Care. 2000;23:192-6. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10868830].
329 Petranyi G, Petranyi M, Scobie IN, et al. Quality control of home monitoring of blood glucose concentrations. Br Med J (Clin Res Ed). 1984;288:757. Not an evaluation of a QI intervention.
330 Philis-Tsimikas A, Walker C. Improved care for diabetes in underserved populations. J Ambul Care Manage. 2001;24:39-43. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11189795].
331 Pichert JW. Outcomes of a diabetes professional education seminar. Diabetes Educ. 1984;9:37-9. Study design did not meet criteria for RCT, CBA, or ITS ble outcomes. [pmid: 6559687].
332 Pichert JW, Penha ML. Institutionalization of diabetes care and education programs: a tale of two cities. Diabetes Educ 1993; 19:273, 276–7. Not an evaluation of a QI intervention
333 Pieber. Evaluation of a structured teaching and treatment programme for type2 diabetes in general practice in a rural area of Austria. Diabetes Medicine. 1995;112:349-54. Patient education or self-management only.
334 Piette JD, Mah CA. The feasibility of automated voice messaging as an adjunct to diabetes outpatient care. Diabetes Care. 1997;20:15-21. Study design did not meet criteria for RCT, CBA, or ITS ble outcomes. [pmid: 9028687].
335 Piette JD. Perceived access problems among patients with diabetes in two public systems of care. J Gen Intern Med. 2000;15:797-804. No eligible outcomes. [pmid: 11119172]. [pmcid: 1495616].
336 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: a randomized, controlled trial. Med Care. 2000;38:218-30. No eligible outcomes. [pmid: 10659695].
337 Pill R, Stott NC, Rollnick SR, Rees M. A randomized controlled trial of an intervention designed to improve the care given in general practice to Type II diabetic patients: patient outcomes and professional ability to change behaviour. Fam Pract. 1998;15:229-35. Patient education or self-management only. [pmid: 9694180].
338 Piwernetz K, Renner R, Mohrlein A, et al. Analysis and processing of data in a hospital-based diabetes management system. Horm Metab Res Suppl. 1990;24:109-15. Not an evaluation of a QI intervention. [pmid: 2272615].
339 Porter AM. Organisation of diabetic care [letter]. British Medical Journal Clinical Research Ed. 1982;285:1121. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 6812777].
340 Prasad S, Kamath GG, Jones K, Clearkin LG, Phillips RP. Effectiveness of optometrist screening for diabetic retinopathy using slit-lamp biomicroscopy. Eye. 2001;15:595-601. No eligible outcomes. [pmid: 11702969].
341 Pratt, et al. Peer support and nutrition education for older adults with diabetes. J Nutr Elder. 1987;6:31. Patient education or self-management only. [pmid: 3656067].
342 Probert CS, Maddison W, Roland JM. Diet, diabetes, and male chauvinism. BMJ. 1990;301:1430-1. No eligible outcomes. [pmid: 2279163]. [pmcid: 1679831].
343 Pugh KB, Jenkins AJ, Zheng D, Chinniss S, Hermayer K, Jenkins C. Foot problems and foot care practices in diabetes. A survey of public and private diabetes clinics affiliated with a university hospital. J S C Med Assoc. 2002;98:305-10. Not an evaluation of a QI intervention. [pmid: 12532656].
344 Quevedo SF, Blenkiron P, Lynch K. Diabetes case management: experience in the staff and IPA model HMO. HMO Pract. 1998;12:44-6. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10178377].
345 Quinn DC, Graber AL, Elasy TA, Thomas J, Wolff K, Brown A. Overcoming turf battles: developing a pragmatic, collaborative model to improve glycemic control in patients with diabetes. Jt Comm J Qual Improv. 2001;27:255-64. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11367773].
346 Rabkin SW, Boyko E, Wilson A, Streja DA. A randomized clinical trial comparing behavior modification and individual counseling in the nutritional therapy of non-insulin-dependent diabetes mellitus: comparison of the effect on blood sugar, body weight, and serum lipids. Diabetes Care. 1983;6:50-6. Patient education or self-management only. [pmid: 6341015].
347 Raji A, Gomes H, Beard JO, MacDonald P, Conlin PR. A randomized trial comparing intensive and passive education in patients with diabetes mellitus. Arch Intern Med. 2002;162:1301-4. Patient education or self-management only. [pmid: 12038949].
348 Ratner RE. CLIA 1988: impact on diabetes care. Diabetes Care. 1992;15:1814-7. Not an evaluation of a QI intervention. [pmid: 1468320].
349 Raz I, Soskolne V, Stein P. Influence of small-group education sessions on glucose homeostasis in NIDDM. Diabetes Care. 1988;11:67-71. Patient education or self-management only. [pmid: 3338379].
350 Redhead J, Hussain A, Gedling P, McCulloch AJ. The effectiveness of a primary-care-based diabetes education service. Diabet Med. 1993;10:672-5. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 8403831].
351 Reiber GE, Smith DG, Boone DA, et al. Design and pilot testing of the DVA/Seattle Footwear System for diabetic patients with foot insensitivity. J Rehabil Res Dev. 1997;34:1-8. Not an evaluation of a QI intervention /No eligible outcomes. [pmid: 9021621].
352 Renders CM, Valk GD, Griffin SJ, Wagner EH, Eijk Van JT, Assendelft WJ. Interventions to improve the management of diabetes in primary care, outpatient, and community settings: a systematic review. Diabetes Care. 2001;24:1821-33. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11574449].
353 Renders CM, Valk GD, Griffin SJ, Wagner EH, Eijk Van JT, Assendelft WJ. Interventions to improve the management of diabetes mellitus in primary care, outpatient and community settings. Cochrane Database Syst Rev 2001:CD001481. Not an evaluation of a QI intervention
354 Riddle MC. A strategy for chronic disease. Lancet. 1980;2:734-6. Not an evaluation of a QI intervention. [pmid: 6106839].
355 Ridgeway NA, Harvill DR, Harvill LM, Falin TM, Forester GM, Gose OD. Improved control of type 2 diabetes mellitus: a practical education/behavior modification program in a primary care clinic. South Med J. 1999;92:667-72. Patient education or self-management only. [pmid: 10414474].
356 Rimmer JH, Silverman K, Braunschweig C, Quinn L, Liu Y. Feasibility of a health promotion intervention for a group of predominantly African American women with type 2 diabetes. Diabetes Educ. 2002;28:571-80. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12224197].
357 Rith-Najarian S, Branchaud C, Beaulieu O, Gohdes D, Simonson G, Mazze R. Reducing lower-extremity amputations due to diabetes. Application of the staged diabetes management approach in a primary care setting. J Fam Pract. 1998;47:127-32. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9722800].
358 Roberts S. Effectiveness of a hospital diabetes specialist nursing service. Diabet Med. 2002;19(Suppl 1):9-11. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11871424].
359 Robinson TN. Community health behavior change through computer network health promotion: preliminary findings from Stanford Health-Net. Computer Methods Programs Biomed. 1989;30:137. Not an evaluation of a QI intervention /No eligible outcomes.
360 Rodgers J, Walker R. Glycaemic control in type 2 diabetes. Nurs Times. 2002;98:56-7. Not an evaluation of a QI intervention. [pmid: 12035400].
361 Rothman R, Malone R, Bryant B, Horlen C, Pignone M, IN. Pharmacist-led, primary care-based disease management improves hemoglobin A1c in high-risk patients with diabetes. American Journal of Medical Quality 2003; 18:51–58. Study design did not meet criteria for RCT, CBA, or ITS
362 Rotman. A randomized controlled trial of a computer-based physician workstation in an outpatient setting: implementation barriers to outcome evaluation. J Am Med Inform Assoc. 1996;3:340. Excluded topic (unrelated to diabetes)/No eligible outcomes. [pmid: 8880681]. [pmcid: 116318].
363 Rotvold GH, Knarvik U, Johansen MA, Fossen K. Telemedicine screening for diabetic retinopathy: staff and patient satisfaction. J Telemed Telecare. 2003;9:109-13. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 12699582].
364 Rubin RJ, Dietrich KA, Hawk AD. Clinical and economic impact of implementing a comprehensive diabetes management program in managed care. J Clin Endocrinol Metab. 1998;83:2635-42. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9709924].
365 Rundall TG, Shortell SM, Wang MC, et al. As good as it gets? Chronic care management in nine leading US physician organisations. BMJ. 2002;325:958-61. Not an evaluation of a QI intervention. [pmid: 12399351]. [pmcid: 1124449].
366 Ruoff G, Gray LS. Using a flow sheet to improve performance in treatment of elderly patients with type 2 diabetes. Fam Med. 1999;31:331-6. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10407711].
367 Rutten G, van Eijk J, de Nobel E, Beek M, van der Velden H. Feasibility and effects of a diabetes type II protocol with blood glucose self-monitoring in general practice. Fam Pract. 1990;7:273-8. Patient education or self-management only. [pmid: 2289639].
368 Ryff-de Leche A, Engler H, Nutzi E, Berger M, Berger W. Clinical application of two computerized diabetes management systems: comparison with the log-book method. Diabetes Res. 1992;19:97-105. Excluded topic (Type 1 diabetes only). [pmid: 1344707].
369 Sacerdote AS. Impact of budget cuts on diabetic control in urban adult diabetes clinic. Diabetes Care. 1988;11:302-3. Not an evaluation of a QI intervention. [pmid: 3416693].
370 Samaras K, Ashwell S, Mackintosh AM, Fleury AC, Campbell LV, Chisholm DJ. Will older sedentary people with non-insulin-dependent diabetes mellitus start exercising? A health promotion model. Diabetes Res Clin Pract. 1997;37:121-8. Patient education or self-management only. [pmid: 9279482].
371 Sanders KM, Satyvavolu A. Improving blood pressure control in diabetes: limitations of a clinical reminder in influencing physician behavior. J Contin Educ Health Prof. 2002;22:23-32. No eligible outcomes. [pmid: 12004637].
372 Sarkisian. A systematic review of diabetes self-care interventions for older, African American, or Latino adults. Diabetes Educ. 2003;29:467. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12861963].
373 Schachat AP, Lee PP, Wu WC. A quality assurance program for an inpatient department of ophthalmology. ‘Indicators and criteria’. Arch Ophthalmol. 1989;107:1293-6. Not an evaluation of a QI intervention. [pmid: 2783061].
374 Schneider SH, Khachadurian AK, Amorosa LF, Clemow L, Ruderman NB. Ten-year experience with an exercise-based outpatient life-style modification program in the treatment of diabetes mellitus. Diabetes Care. 1992;15:1800-10. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 1468318].
375 Scholz V, Jorgens V, Berger M, et al. Evaluation of a postgraduate course for diabetes educators. Diabetes Educ. 1984;10(SPEC NO):80-4. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 6564020].
376 Schwartz R, Zaremba M, Ra K. Third-party coverage for diabetes education program. QRB Qual Rev Bull. 1985;11:213-7. Not an evaluation of a QI intervention. [pmid: 3929205].
377 Schwedes U, Siebolds M, Mertes G. Meal-related structured self-monitoring of blood glucose: effect on diabetes control in non-insulin-treated type 2 diabetic patients. Diabetes Care. 2002;25:1928-32. Patient education or self-management only. [pmid: 12401734].
378 Scott, et al. The effectiveness of diabetes education for non-insulin-dependent diabetic persons. Diabetes Educ. 1984;10:36. Patient education or self-management only. [pmid: 6562009].
379 Scott M. The NSW Aboriginal Vascular Health Program. N S W Public Health Bull. 2002;13:152-4. Not an evaluation of a QI intervention. [pmid: 12451409].
380 Sczupak CA, Conrad WF. Relationship between patient-oriented pharmaceutical services and therapeutic outcomes of ambulatory patients with diabetes mellitus. American Journal of Hospital Pharmacy. 1977;34:1238-1242. Publication prior to 1980. [pmid: 930938].
381 Shandro MT, Pick ME, Gruninger A, Ryan EA, IN. Diabetes care: interventions in the community. Diabetes Care 2002; 25:941–942. Patient education or self-management only
382 Sharp LK, Lipsky MS. The short-term impact of a continuing medical education program on providers' attitudes toward treating diabetes. Diabetes Care. 1999;22:1929-32. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 10587820].
383 Sharp LK, Lipsky MS. Continuing medical education and attitudes of health care providers toward treating diabetes. J Contin Educ Health Prof. 2002;22:103-12. No eligible outcomes. [pmid: 12099119].
384 Shultz EK, Bauman A, Hayward M, Rodbard D, Holzman R. Improved diabetic prognosis following telecommunication and graphical processing of diabetic data. Proc Annu Symp Comput Appl Med Care 1991:53–7. Duplicate/overlap of article #385 from this table) Overlaps with or duplicates another article that was included
385 Shultz EK, Bauman A, Hayward M, Holzman R. Improved care of patients with diabetes through telecommunications. Ann N Y Acad Sci. 1992;670:141-5. Other ^§§§^ §§§ Cross-over trial with insufficient wash out period and insufficient information to split into two. [pmid: 1309083].
386 Sibbald RG, Kensholme A, Carter L, Knowles A, Tyrrell W. Special foot clinics for patients with diabetes. J Wound Care. 1996;5:238-43. Not an evaluation of a QI intervention. [pmid: 8850908].
387 Siddall R. Diabetes. Sugar refiner. Health Serv J. 1999;109(suppl):3-5. Not an evaluation of a QI intervention. [pmid: 10621294].
388 Sideman K, Padilla B, Huff TA, Stachura ME. Capillary blood glucose monitoring: a comparison of two hospital quality control programs. Diabetes Educ. 1988;14:223-6. Not an evaluation of a QI intervention /Excluded topic (capillary blood glucose testing). [pmid: 3371167].
389 Sidorov J, Gabbay R, Harris R, et al. Disease management for diabetes mellitus: impact on hemoglobin A1c. Am J Manag Care. 2000;6:1217-26. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11185847].
390 Sidorov J, Shull R, Tomcavage J, Girolami S, Lawton N, Harris R. Does diabetes disease management save money and improve outcomes? A report of simultaneous short-term savings and quality improvement associated with a health maintenance organization-sponsored disease management program among patients fulfilling health employer data and information set criteria. Diabetes Care. 2002;25:684-9. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11919125].
391 Sifuentes F, Chang L, Nieman LZ, Foxhall LE. Evaluating a diabetes foot care program in a preceptorship for medical students. Diabetes Educ 2002; 28:930–2, 935–7. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes
392 Sikka R, Waters J, Moore W, Sutton DR, Herman WH, Aubert RE. Renal assessment practices and the effect of nurse case management of health maintenance organization patients with diabetes. Diabetes Care. 1999;22:1-6. (Duplicate/overlap of included article^****^ **** Aubert, R.E., Herman, W.H., Waters, J., et al. Nurse case management to improve glycemic control in diabetic patients in a health maintenance organization. A randomized, controlled trial. Ann Intern Med. 1998;129(8):605–12. ) Overlaps with or duplicates another article that was included. [pmid: 10333895].
393 Simmons D, Voyle JA. Reaching hard-to-reach, high-risk populations: piloting a health promotion and diabetes disease prevention programme on an urban marae in New Zealand. Health Promot Internation. 2003;18:41-50. Study design did not meet criteria for RCT, CBA, or ITS/Excluded topic (promotion of diabetes prevention program).
394 Singh BM, Holland MR, Thorn PA. Metabolic control of diabetes in general practice clinics: comparison with a hospital clinic. Br Med J (Clin Res Ed). 1984;289:726-8. Not an evaluation of a QI intervention.
395 Sinnock P. The use of hospitalization data to evaluate patient education programs. Diabetes Educ. 1984;10(SPEC NO):43-5. Not an evaluation of a QI intervention. [pmid: 6564012].
396 Skaer TL, Sclar DA, Markowski DJ, Won JK. Effect of value-added utilities on prescription refill compliance and Medicaid health care expenditures—a study of patients with non-insulin-dependent diabetes mellitus. J Clin Pharm Ther. 1993;18:295-9. Patient education or self-management only. [pmid: 8227238].
397 Smith DM, Norton JA, Weinberger M, McDonald CJ, Katz BP. Increasing prescribed office visits. A controlled trial in patients with diabetes mellitus. Med Care. 1986;24:189-99. (Duplicate/overlap of article #398 from this table) Overlaps with or duplicates another article that was included. [pmid: 3512926].
398 Smith DM, Weinberger M, Katz BP. A controlled trial to increase office visits and reduce hospitalizations of diabetic patients. J Gen Intern Med. 1987;2:232-8. Patient education or self-management only. [pmid: 3612344].
399 Smith SC, Folk JC, Losch ME. Effects of collaborative education on patient satisfaction and knowledge. Insight. 1992;17:20-4. No eligible outcomes. [pmid: 1564366].
400 Smith DE, Heckemeyer CM, Kratt PP, Mason DA. Motivational interviewing to improve adherence to a behavioral weight-control program for older obese women with NIDDM. A pilot study. Diabetes Care. 1997;20:52-4. Patient education or self-management only. [pmid: 9028693].
401 Smith L, Weinert C. Telecommunication support for rural women with diabetes. Diabetes Educ. 2000;26:645-55. No eligible outcomes. [pmid: 11140073].
402 Snoek FJ, Skinner TC. Psychological counselling in problematic diabetes: does it help?. Diabet Med. 2002;19:265-73. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11942996].
403 Solberg LI, Reger LA, Pearson TL, et al. Using continuous quality improvement to improve diabetes care in populations: the IDEAL model. Improving care for Diabetics through Empowerment Active collaboration and Leadership. Jt Comm J Qual Improv. 1997;23:581-92. Not an evaluation of a QI intervention. [pmid: 9407262].
404 Sperl-Hillen J, O'Connor PJ, Carlson RR, et al. Improving diabetes care in a large health care system: an enhanced primary care approach. Jt Comm J Qual Improv. 2000;26:615-22. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11098424].
405 Sperl-Hillen J, Isham GJ. HealthPartners' diabetes care improvement program. Healthplan 2002; 43:46–8, 50–1, 53. Not an evaluation of a QI intervention
406 Sprafka JM, Crozier M, Whipple D, Bishop D, Kurth D. Response of diabetic patients to a community-based education program. Diabetes Educ. 1988;14:148-51. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3349916].
407 Stafford J, Helm AM, Beaven DW. The value of short courses: an attempt ot evaluate a four-day teaching programme in Christchurch for diabetes educators. New Zealand Nursing Journal. 1979;72:24. Not an evaluation of a QI intervention. [pmid: 289040].
408 Stange KC, Miller WL, Crabtree BF, O'Connor PJ, Zyzanski SJ. Multimethod research: approaches for integrating qualitative and quantitative methods. J Gen Intern Med. 1994;9:278-82. Not an evaluation of a QI intervention. [pmid: 8046531].
409 Starren J, Hripcsak G, Sengupta S, et al. Columbia University's Informatics for Diabetes Education and Telemedicine (IDEATel) project: technical implementation. J Am Med Inform Assoc. 2002;9:25-36. Not an evaluation of a QI intervention. [pmid: 11751801]. [pmcid: 349385].
410 Steel JM, Cramb R, Duncan LJ. How useful are patient-operated blood glucose meters?. Practitioner. 1980;224:651-3. Not an evaluation of a QI intervention. [pmid: 7422613].
411 Steffens B. Cost-effective management of type 2 diabetes: providing quality care in a cost-constrained environment. Am J Manag Care. 2000;6:S697-703. discussion S704–9. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11183422].
412 Stegmayer P, Lovrien FC, Smith M, Keller T, Gohdes DM. Designing a diabetes nutrition education program for a Native American community. Diabetes Educ. 1988;14:64-6. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 3335190].
413 Stein GH. The use of a nurse practitioner in the management of patients with diabetes mellitus. Medical Care. 1974;12:885-890. Not an evaluation of a QI intervention. [pmid: 4437220].
414 Stoner KL, Lasar NJ, Butcher MK, et al. Improving glycemic control: can techniques used in a managed care setting be successfully adapted to a rural fee-for-service practice?. Am J Med Qual. 2001;16:93-8. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11392175].
415 Stott NC, Rollnick S, Rees MR, Pill RM. Innovation in clinical method: diabetes care and negotiating skills. Fam Pract. 1995;12:413-8. Not an evaluation of a QI intervention. [pmid: 8826057].
416 Strock ES, Sandell JL. The ambulatory insulin program: initiating insulin therapy in an outpatient setting. Diabetes Educ. 1988;14:338-45. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 3289870].
417 Sturmberg JP, Overend D. General practice based diabetes clinics. An integration model. Aust Fam Physician. 1999;28:240-5. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 10098303].
418 Sullivan FM. Whose problem is the diabetic who does not attend a hospital clinic?. Scott Med J. 1988;33:259-60. Not an evaluation of a QI intervention. [pmid: 3175601].
419 Sullivan FM, Menzies A. The costs and benefits of introducing a nurse-run diabetic review service into general practice. Practical Diabetes. 1991;8(2):47-50. Study design did not meet criteria for RCT, CBA, or ITS.
420 Surwit RS, van Tilburg MA, Zucker N, et al. Stress management improves long-term glycemic control in type 2 diabetes. Diabetes Care. 2002;25:30-4. Patient education or self-management only. [pmid: 11772897].
421 Svac J. Analysis of discharge data in a large hospital in Slovakia. Its application to diabetic patients. Stud Health Technol Inform. 1994;14:110-23. Not an evaluation of a QI intervention. [pmid: 10163679].
422 Tai SS, Nazareth I, Donegan C, Haines A. Evaluation of general practice computer templates. Lessons from a pilot randomised controlled trial. Methods Inf Med. 1999;38:177-81. Study design did not meet criteria for RCT, CBA, or ITS/No eligible outcomes. [pmid: 10522120].
423 Tape TG, Campbell JR. Computerized medical records and preventive health care: success depends on many factors. Am J Med. 1993;94:619-25. No eligible outcomes. [pmid: 8506888].
424 Taplin S, Galvin MS, Payne T, Coole D, Wagner E. Putting population-based care into practice: real option or rhetoric?. J Am Board Fam Pract. 1998;11:116-26. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9542703].
425 Tariq SH, Karcic E, Thomas DR, et al. The use of a no-concentrated-sweets diet in the management of type 2 diabetes in nursing homes. J Am Diet Assoc. 2001;101:1463-6. Not an evaluation of a QI intervention. [pmid: 11762744].
426 Tasker PR. Diabetes care: whose responsibility?. Br Med J (Clin Res Ed). 1985;290:1632. Not an evaluation of a QI intervention.
427 Tattersall R, Gale E. Patient self-monitoring of blood glucose and refinements of conventional insulin treatment. Am J Med. 1981;70:177-82. Not an evaluation of a QI intervention. [pmid: 7006390].
428 Taylor R. Practical community screening for diabetic retinopathy using the mobile retinal camera: report of a 12 centre study. British Diabetic Association Mobile Retinal Screening Group. Diabet Med. 1996;13:946-52. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 8946152].
429 Testa MA, Simonson DC. Health economic benefits and quality of life during improved glycemic control in patients with type 2 diabetes mellitus: a randomized, controlled, double-blind trial. JAMA. 1998;280:1490-6. Not an evaluation of a QI intervention. [pmid: 9809729].
430 Teza SL, DeVito AV 2nd, Hiss RG. Resource manual to help your program meet the national standards. Diabetes Educ. 1987;13(Suppl):210-28. Not an evaluation of a QI intervention. [pmid: 3646957].
431 Thackeray R, Neiger BL. Using social marketing to develop diabetes self-management education interventions. Diabetes Educ 2002; 28:536–40, 542–4. Not an evaluation of a QI intervention
432 Thompson. A team approach to diabetic foot care: the Manchester experience. Foot. 1991;1:75-82. Other ˆˆˆˆ ˆˆˆˆ ˆˆˆ Unable to obtain article.
433 Thorn PA, Watkins PJ. Organisation of diabetic care. Br Med J (Clin Res Ed). 1982;285:787-9. Not an evaluation of a QI intervention.
434 Tildesley HD, Mair K, Sharpe J, Piaseczny M. Diabetes teaching—outcome analysis. Patient Educ Couns. 1996;29:59-65. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 9006222].
435 Tobe SW, McFarlane PA, Naimark DM. Microalbuminuria in diabetes mellitus. CMAJ. 2002;167:499-503. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12240818]. [pmcid: 121969].
436 Trento M, et al. Therapeutic group education in the follow-up of patients with non-insulin treated, non-insulin dependent diabetes mellitus. Diabetes Metab Clin Exp. 1998;11:212-216. Patient education or self-management only.
437 Trento M, Passera P, Tomalino M, et al. Group visits improve metabolic control in type 2 diabetes: a 2-year follow-up. Diabetes Care. 2001;24:995-1000. Patient education or self-management only. [pmid: 11375359].
438 Trento M, Passera P, Bajardi M, et al. Lifestyle intervention by group care prevents deterioration of Type II diabetes: a 4-year randomized controlled clinical trial. Diabetologia. 2002;45:1231-9. Patient education or self-management only. [pmid: 12242455].
439 Tsang MW, Mok M, Kam G, et al. Improvement in diabetes control with a monitoring system based on a hand-held, touch-screen electronic diary. J Telemed Telecare. 2001;7:47-50. Patient education or self-management only. [pmid: 11265938].
440 Tu KS, McDaniel G, Gay JT. Diabetes self-care knowledge, behaviors, and metabolic control of older adults—the effect of a posteducational follow-up program. Diabetes Educator. 1993;19:25-30. Patient education or self-management only. [pmid: 8458295].
441 Turner RC, Peden JG Jr, O'Brien K. Patient-carried card prompts vs computer-generated prompts to remind private practice physicians to perform health maintenance measures. Arch Intern Med. 1994;154:1957-60. No eligible outcomes. [pmid: 8074599].
442 Turnin MC, Beddok RH, Clottes JP, et al. Telematic expert system Diabeto. New tool for diet self-monitoring for diabetic patients. Diabetes Care. 1992;15:204-12. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 1547677].
443 Tyrrell W. Orthotic intervention in patients with diabetic foot ulceration. J Wound Care. 1999;8:530-2. Not an evaluation of a QI intervention. [pmid: 10827660].
444 Uusitupa, et al. The maintenance of improved metabolic control after intensified diet therapy in recent type 2 diabetes. Diabetes Res Clinic Pract. 1993;19:227. Patient education or self-management only.
445 Uusitupa MI. Early lifestyle intervention in patients with non-insulin-dependent diabetes mellitus and impaired glucose tolerance. Ann Med. 1996;28:445-9. (Duplicate/overlap of article #444 from this table) Overlaps with or duplicates another article that was included. [pmid: 8949977].
446 Valk GD, Kriegsman DM, Assendelft WJ. Patient education for preventing diabetic foot ulceration. A systematic review. Endocrinol Metab Clin North Am. 2002;31:633-58. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 12227125].
447 Varroud-Vial M, Charpentier G, Vaur L, et al. Effects of clinical audit on the quality of care in patients with type 2 diabetes: results of the DIABEST pilot study. Diabetes Metab. 2001;27:666-74. Not an evaluation of a QI intervention. [pmid: 11852375].
448 Vijan S, Stevens DL, Herman WH, Funnell MM, Standiford CJ. Screening, prevention, counseling, and treatment for the complications of type II diabetes mellitus. Putting evidence into practice. J Gen Intern Med. 1997;12:567-80. Not an evaluation of a QI intervention. [pmid: 9294791]. [pmcid: 1497162].
449 Vinicor F, Cohen SJ, Mazzuca SA, et al. DIABEDS: a randomized trial of the effects of physician and/or patient education on diabetes patient outcomes. Journal of Chronic Diseases. 1987;40:345-356. (Duplicate/overlap of included articleˆˆ) Overlaps with or duplicates another article that was included. [pmid: 3549757].
450 Vrijhoef HJ, Diederiks JP, Spreeuwenberg C, Wolffenbuttel BH. Substitution model with central role for nurse specialist is justified in the care for stable type 2 diabetic outpatients. J Adv Nurs. 2001;36:546-55. No eligible outcomes. [pmid: 11703549].
451 Vrijhoef HJ, Spreeuwenberg C, Eijkelberg IM, Wolffenbuttel BH, van Merode GG. Adoption of disease management model for diabetes in region of Maastricht. BMJ. 2001;323:983-5. Not an evaluation of a QI intervention. [pmid: 11679390]. [pmcid: 1121511].
452 Vrijhoef HJ, Diederiks JP, Spreeuwenberg C, Wolffenbuttel BH, van Wilderen LJ, IN. The nurse specialist as main care-provider for patients with type 2 diabetes in a primary care setting: effects on patient outcomes. International Journal of Nursing Studies 2002; 39:441–451. Study design did not meet criteria for RCT, CBA, or ITS ble outcomes
453 Watkins GB, Sutcliffe T, Pyke DA, Watkins PJ. Computerisation of diabetic clinic records. Br Med J. 1980;281:1402-3. Not an evaluation of a QI intervention. [pmid: 7437814]. [pmcid: 1715014].
454 Watts GF, Macleod AF, Benn JJ, et al. Comparison of the real-time use of glycosylated haemoglobin and plasma fructosamine in the diabetic clinic. Diabet Med. 1991;8:573-9. Not an evaluation of a QI intervention. [pmid: 1832359].
455 Weinberger M, Ault KA, Vinicor F. Prospective reimbursement and diabetes mellitus. Impact upon glycemic control and utilization of health services. Med Care. 1988;26:77-83. Study design did not meet criteria for RCT, CBA, or ITS No eligible outcomes. [pmid: 3336246].
456 Weinberger M, Oddone EZ, Henderson WG. Does increased access to primary care reduce hospital readmissions? Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. N Engl J Med. 1996;334:1441-7. No eligible outcomes. [pmid: 8618584].
457 Werdier D, Jesdinsky HJ, Helmich P. A randomized, controlled study on the effect of diabetes counseling in the offices of 12 general practitioners. Rev Epidemiol Sante Publique. 1984;32:225-9. Patient education or self-management only. [pmid: 6522737].
458 White N, Carnahan J, Nugent CA, Iwaoka T, Dodson MA. Management of obese patients with diabetes mellitus: comparison of advice education with group management. Diabetes Care. 1986;9:490-6. Patient education or self-management only. [pmid: 3769719].
459 White B. 13 months of quality improvement: did it work?. Fam Pract Manag. 2001;8:55-7. Study design did not meet criteria for RCT, CBA, or ITS. [pmid: 11317859].
460 Williams D, Munroe C, Hospedales CJ, Greenwood RH. A Three-Year Evaluation of the Quality of Diabetes Care in the Norwich Community Care Scheme. Diab Medicine. 1990;7:74. Study design did not meet criteria for RCT, CBA, or ITS.
461 Wilson W, Pratt C. The impact of diabetes education and peer support upon weight and glycemic control of elderly persons with noninsulin dependent diabetes mellitus (NIDDM). Am J Public Health. 1987;77:634-5. Patient education or self-management only. [pmid: 3565666]. [pmcid: 1647053].
462 Wing RR, Epstein LH, Nowalk MP, Scott N, Koeske R, Hagg S. Does self-monitoring of blood glucose levels improve dietary compliance for obese patients with type II diabetes?. Am J Med. 1986;81:830-6. Patient education or self-management only. [pmid: 3535493].
463 Wing. Self-regulation in the treatment of type II diabetes. Behav Ther. 1988;19:11. (Duplicate/overlap of article #462 from this table) Overlaps with or duplicates another article that was included.
464 Wing RR, Anglin K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. 1996;19:409-13. No eligible outcomes. [pmid: 8732700].
465 Wise PH, Dowlatshahi DC, Farrant S, Fromson S, Meadows KA. Effect of computer-based learning on diabetes knowledge and control. Diabetes Care. 1986;9:504-8. Patient education or self-management only. [pmid: 3533475].
466 Woodcock AJ, Kinmonth AL, Campbell MJ, Griffin SJ, Spiegal NM. Diabetes care from diagnosis: effects of training in patient-centred care on beliefs, attitudes and behaviour of primary care professionals. Patient Educ Couns. 1999;37:65-79. No eligible outcomes. [pmid: 10640121].
467 Wooldridge J, Moreno L. Evaluation of the costs to Medicare of covering therapeutic shoes for diabetic patients. Diabetes Care. 1994;17:541-547. No eligible outcomes. [pmid: 8082522].
468 Worth. Shared care for diabetes in Chester: preliminary experience with a ‘clinic-wide’ scheme. Practical Diabetes. 1990;7:266. Study design did not meet criteria for RCT, CBA, or ITS.
469 Wylie-Rosett J, Engel S, D'Eramo G, et al. Delivery of diabetes care to low—income patients: assessment of a federally funded program. Diabetes Educ. 1989;15:366-9. Not an evaluation of a QI intervention. [pmid: 2791863].
470 Wylie-Rosett J, Villeneuve M, IN. Overcoming resistance to change in a long-term care facility: analysis of the team approach and consensus process. Diabetes Educator. 1989; 15:122–123. Not an evaluation of a QI intervention
471 Young-Hyman D. Provider impact in diabetes education. What we know, what we would like to know, paradigms for asking. Diabetes Educ. 1999;25:34-42. Not an evaluation of a QI intervention. [pmid: 10711083].