# Calculation of effective sample sizes for trials with clustering

A substantial number of studies exhibited “clustering,” in that the units of analysis were patient level outcomes but the unit of allocation had been clusters of patients (e.g., randomization involved providers or clinics). The significance of clustering is that patients within a cluster are not independent - i.e., patients at one clinic have greater resemblance to each other than to patients at other sites or cared for by other providers in the trial. Unit of analysis errors do not affect point estimates for effect sizes, but they may spuriously narrow the associated confidence interval, potentially leading to a false-positive result in a trial. ^1^ – ^8^ To avoid the same inflation of precision in our analysis, we calculated an effective sample size* for each study. Importantly, from the point of view of our analysis, the degree to which investigators acknowledged or accounted for cluster effects did not affect our analysis, except in so far as investigators who did consider cluster effects in the design or analysis of the trial were more likely to report data such as the number of providers randomized, rather than just the total numbers of patients in each group, as well as provide more technical details, such as values for the intra-cluster coefficient (ICC). ^9^ – ^11^

The table below compares the effective and originally reported sample sizes for effective sample sizes. Only values at baseline in the control and intervention groups are shown, but the same calculations were carried out for reported sample sizes in the post-intervention period for all study groups. Because so few studies reported ICC values, ^9^ – ^11^ we imputed values based on published estimates. Specifically, we used ICC=0.03 for the HbA1c outcome and ICC=0.10 for measures of provider adherence, based no the midpoints of published values for process and outcome measures in primary care settings. ^3^ As a sensitivity analysis, we re-ran the effective sample size calculations and regression analyses with the upper bounds of these ranges (ICC=0.10 and ICC=0.33, for outcome and process measures, respectively), with no substantial impacts no the results.

Table F1 Reported vs. effective sample sizes for clustered studies evaluating reduction in HbA_1c_

| No. of clusters | Reported N(patients) | Effective N(patients) | Percent reduction (%)
Benjamin 1999 ^12^ | 2 | 106 | 46 | 57
Boucher 1997 ^13^ | 6 | 183 | 105 | 43
Olivarius 2001 ^14^ | 484 | 874 | 857 | 2
de Sonnaville 1997 ^15^ | 28 | 563 | 376 | 33
Frijling 2002 ^9^ | 123 | 1430 | 1128 | 21
Groeneveld 2001 ^16^ | 15 | 224 | 165 | 26
Hetlevik 2000 ^17^ | 30 | 733 | 452 | 38
Hirsch 2002 ^18^ | 2 | 109 | 46 | 58
Kiefe 2001 ^19^ | 84 | 1352 | 974 | 28
Kinmonth 1998 ^10^ | 42 | 240 | 197 | 18
Kogan 2003 ^20^ | 44 | 283 | 249 | 12
Litzelman 1993 ^21^ | 4 | 353 | 111 | 69
Mazzuca 1986 ^22^ | 13 | 127 | 104 | 18
McDermott 2001 ^23^ | 21 | 678 | 380 | 44
Meigs 2003 ^11^ | 66 | 598 | 377 | 37
O'Connor 1996 ^24^ | 2 | 241 | 60 | 75
Ovhed 2000 ^25^ | 2 | 394 | 66 | 83
Reed 2001 ^26^ | 9 | 189 | 123 | 35
Renders 2001 ^27^ | 27 | 389 | 291 | 25
Wagner 2001 ^28^ | 34 | 609 | 425 | 30
Walker 2001 ^29^ | 2 | 345 | 65 | 81
Deeb 1988 ^30^ | 6 | 636 | 173 | 73
Feder 1995 ^31^ | 24 | 21 | 21 | 0
Legorreta 1996 ^32^ | 2 | 205 | 58 | 72
Hartmann 1995 ^33^ | 17 | 376 | 246 | 35
Walker 2001 ^29^ | 2 | 345 | 65 | 81
Legorreta 1996 ^32^ | 2 | 185 | 55 | 70
Branger 1999 ^34^ | 32 | 275 | 227 | 17
Mazzuca 1986 ^22^ | 14 | 120 | 101 | 16

* Effective N equals sample size adjusted for presence of clustering. It was calculated as N_Effective_ = (k*m) / (1 + (m-1)*r), where 'k 'is the number of clusters, ‘m’ is the number of patients per cluster, and ‘r’ is the intracluster coefficient (ICC). When r = 0, then N_Effective_ = k*m (i.e., the reported sample size) When r = 1, then N_Effective_ = k(i.e., the number of clusters) ^1^ – ^8^

## Appendix F References

1 Kerry SM, Bland JM. Sample size in cluster randomisation. BMJ. 1998;316:549. [pmid: 9501723].
2 Kerry SM, Bland JM. Statistics notes: The intracluster correlation coefficient in cluster randomisation. BMJ. 1998;316:1455-1460. [pmid: 9572764]. [pmcid: 1113123].
3 Campbell MK, Mollison J, Grimshaw JM. Cluster trials in implementation research: estimation of intracluster correlation coefficients and sample size. Stat Med. 2001;20:391-399. [pmid: 11180309].
4 Torgerson DJ. Contamination in trials: is cluster randomisation the answer?. BMJ. 2001;322:355-357. [pmid: 11159665]. [pmcid: 1119583].
5 Donner A, Piaggio G, Villar J. Meta-analyses of cluster randomization trials. Power considerations. Eval Health Prof. 2003;26:340-351. [pmid: 12971203].
6 Donner A, Klar N. Issues in the meta-analysis of cluster randomized trials. Stat Med. 2002;21:2971-2980. [pmid: 12325113].
7 Donner A, Piaggio G, Villar J. Statistical methods for the meta-analysis of cluster randomization trials. Stat Methods Med Res. 2001;10:325-338. [pmid: 11697225].
8 Localio AR, Berlin JA, Ten Have TR, Kimmel SE. Adjustments for center in multicenter studies: an overview. Ann Intern Med. 2001;135:112-123. [pmid: 11453711].
9 Frijling BD, Lobo CM, Hulscher ME, et al. Multifaceted support to improve clinical decision making in diabetes care: a randomized controlled trial in general practice. Diabet Med. 2002;19:836-842. [pmid: 12358871].
10 Kinmonth AL, Woodcock A, Griffin S, Spiegal N, Campbell MJ. Randomised controlled trial of patient centred care of diabetes in general practice: impact on current wellbeing and future disease risk. The Diabetes Care From Diagnosis Research Team. BMJ. 1998;317:1202-1208. [pmid: 9794859].
11 Meigs JB, Cagliero E, Dubey A, et al. A controlled trial of web-based diabetes disease management: the MGH diabetes primary care improvement project. Diabetes Care. 2003;26:750-757. [pmid: 12610033].
12 Benjamin EM, Schneider MS, Hinchey KT. Implementing practice guidelines for diabetes care using problem-based learning. A prospective controlled trial using firm systems. Diabetes Care. 1999;22:1672-1678. [pmid: 10526733].
13 Boucher BJ, Claff HR, Edmonson M, et al. A pilot Diabetic Support Service based on family practice attenders: comparison with diabetic clinics in east London. Diabet Med. 1987;4:480-484. [pmid: 2959442].
14 Olivarius NF, Beck-Nielsen H, Andreasen AH, Horder M, Pedersen PA. Randomised controlled trial of structured personal care of type 2 diabetes mellitus. BMJ. 2001;323:970-975. [pmid: 11679387]. [pmcid: 59690].
15 de Sonnaville JJ, Bouma M, Colly LP, Deville W, Wijkel D, Heine RJ. Sustained good glycaemic control in NIDDM patients by implementation of structured care in general practice: 2-year follow-up study. Diabetologia. 1997;40:1334-1340. [pmid: 9389427].
16 Groeneveld Y, Petri H, Hermans J, Springer M, IN. An assessment of structured care assistance in the management of patients with type 2 diabetes in general practice. Scandinavian Journal of Primary Health Care. 2001;Vol 19:30.
17 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. 2000;16:210-227. [pmid: 10815366].
18 Hirsch IB, Goldberg HI, Ellsworth A, et al. A multifaceted intervention in support of diabetes treatment guidelines: a controlled trial. Diabetes Res Clin Pract. 2002;58:27-36. [pmid: 12161054].
19 Kiefe CI, Allison JJ, Williams OD, Person SD, Weaver MT, Weissman NW. Improving quality improvement using achievable benchmarks for physician feedback: a randomized controlled trial. JAMA. 2001;285:2871-2879. [pmid: 11401608].
20 Kogan JR, Reynolds EE, Shea JA. Effectiveness of report cards based on chart audits of residents' adherence to practice guidelines on practice performance: a randomized controlled trial. Teach Learn Med. 2003;15:25-30. [pmid: 12632705].
21 Litzelman DK, Slemenda CW, Langefeld CD, et al. Reduction of lower extremity clinical abnormalities in patients with non-insulin-dependent diabetes mellitus. A randomized, controlled trial. Ann Intern Med. 1993;119:36-41. [pmid: 8498761].
22 Mazzuca SA, Moorman NH, Wheeler ML, et al. The diabetes education study: a controlled trial of the effects of diabetes patient education. Diabetes Care. 1986;9:1-10. [pmid: 3948638].
23 McDermott RA, Schmidt BA, Sinha A, Mills P. Improving diabetes care in the primary healthcare setting: a randomised cluster trial in remote Indigenous communities. Med J Aust. 2001;174:497-502. [pmid: 11419768].
24 O'Connor PJ, Rush WA, Peterson J, et al. Continuous quality improvement can improve glycemic control for HMO patients with diabetes. Arch Fam Med. 1996;5:502-506. [pmid: 8930220].
25 Ovhed I, Johansson E, Odeberg H, Rastam L. A comparison of two different team models for treatment of diabetes mellitus in primary care. Scand J Caring Sci. 2000;14:253-258. [pmid: 12035216].
26 Reed RL, Revel AO, Carter A, Saadi HF, Dunn EV. A clinical trial of chronic care diabetic clinics in general practice in the United Arab Emirates: a preliminary analysis. Arch Physiol Biochem. 2001;109:272-280. [pmid: 11880932].
27 Renders CM, Valk GD, Franse LV, et al. Long-term effectiveness of a quality improvement program for patients with type 2 diabetes in general practice. Diabetes Care. 2001;24:1365-1370. [pmid: 11473071].
28 Wagner EH, Grothaus LC, Sandhu N, et al. Chronic care clinics for diabetes in primary care: a system-wide randomized trial. Diabetes Care. 2001;24:695-700. [pmid: 11315833].
29 Walker EA, Engel SS, Zybert PA, IN. Dissemination of diabetes care guidelines: lessons learned from community health centers. Diabetes Educator. 2001;27:101–110.
30 Deeb LC, Pettijohn FP, Shirah JK, Freeman G. Interventions among primary-care practitioners to improve care for preventable complications of diabetes. Diabetes Care. 1988;11:275-280. [pmid: 3416683].
31 Feder G, Griffiths C, Highton C, Eldridge S, Spence M, Southgate L. Do clinical guidelines introduced with practice based education improve care of asthmatic and diabetic patients? A randomised controlled trial in general practices in east London. BMJ. 1995;311:1473-1478. [pmid: 8520339]. [pmcid: 2543702].
32 Legorreta AP, Peters AL, Ossorio RC, Lopez RJ, Jatulis D, Davidson MB. Effect of a comprehensive nurse-managed diabetes program: an HMO prospective study. Am J Manag Care. 1996;2:1024-1030.
33 Hartmann, et al. Effects of peer-review groups on physicians' practice. Eur J Gen Pract. 1995;1:107.
34 Branger PJ, van't Hooft A, van der Wouden JC, Moorman PW, van Bemmel JH. Shared care for diabetes: supporting communication between primary and secondary care. Int J Med Inf. 1999;53:133-142.