# Summary of results for each included study

Table E1 Main results for glycemic control and provider adherence

Study details | Intervention | Provider adherence outcomes | Disease control outcomes | Patient adherence
Ahring, 1992 ^1^ | Intervention group: Patients transmitted fingerstick readings by telephone system automatically to provider (SMx, FR) | | Disease control: HbA1c
| Control group: no intervention/usual care | | Control: 11.2 ± 1.8→10.2 ± 1.2
| | | Intervention: 10.6 ± 2.8 → 9.2 ± 1.1
| | | Other outcomes: serum blood glucose, weight
Albisser, 1996 ^2^ | Comparison 1: | | Disease control 1: HbA1c
| Intervention group: Patients reported HbA1c values, symptoms, life changes to automated system, received medication/other advice; providers received feedback of patient status (SMx, FR, OC/medrcrd) | | Control: 10.2 ± 1.4→10.3 ± 1.3
| Control group: Registered for, but did not use automated system | | Intervention: 10.1 ± 1.5→8.8 ± 1.4
| | | Other outcomes: weight
| Comparison 2: | | Disease control 1: HbA1c
| Intervention group: Patients reported HbA1c values, symptoms, life changes to automated system, received medication/other advice; providers received feedback of patient status (SMx, FR, OC/medrcrd) | | Control: 8.2 ± 1.9→8.6 ± 1.7
| Control group: Registered for, but did not use automated system | | Intervention: 8.9 ± 1.7→7.9 ± 1.2
| | | Other outcomes: weight
Aubert, 1998 ^3^ | Intervention group: Nurse case management supervised by GP, telephone reminders to patient, diabetes education (PtE, FR, OC/DxMx) | Other outcomes: % patients with dipstick test in past year, % patients with protein/microalbumin test in past year | Other outcomes: median HbA1c, median SBP, median DBP, fasting blood glucose, total cholesterol, HDL-C, LDL-C, triglycerides, weight
| Control group: Diabetes education only
Benjamin, 1999 ^4^ | Intervention group: Providers developed and implemented clinical practice guidelines based on problem-based learning (PvE) | | Disease control: HbA1c
| Control group: no intervention/usual care | | Control: 9.21 ± 2.3→9.15 ± 2.3
| | | Intervention: 9.3 ± 2.4 →8.68 ± 2.1
Boucher, 1987 ^5^ | Intervention group: Diabetes support service gave lists of patients requiring tests to provider, provider education in examination for diabetic fundi (PtR, PvE, FR, OC/medrcrd) | | Disease control: HbA1c
| Control group: no intervention/usual care | | Control: 12.6 ± 3.2→12.5 ± 2.6
| | | Intervention: 13.4 ± 2.9→11.4 ± 2.3
Branger, 1998 ^6^ | Intervention group: Physicians equipped with electronic communication system to facilitate communication between PCP and specialist (FR, OC/other) | | Disease control: HbA1c
| Control group: All providers had electronic patient records | | Control: 6.6 ± NR→ 6.5 ± NR
| | | Intervention: 7.0 ± NR→ 6.8 ± NR
Cagliero, 1999 ^7^ | Intervention group: Patients had HbA1c measured with benchtop analyzer with results immediately available to provider during visit (FR) | | Disease control: HbA1c
| Control group: no intervention/usual care | | Control: 8.49 ± 1.59→ 8.3 ± NR
| | | Intervention: 8.67 ± 1.79→ 8.27 ± NR
Clancy, 2003 ^8^ | Intervention group: Patients had group instead of individual physician visits consisting of education and one-on-one consult (PtE, OC/DxMx/team) | Other outcome: adherence to 8 out of 10 diabetes guidelines
| Control group: no intervention/usual care
Clifford, 2002 ^9^ | Intervention group: Pharmacist monitored patients and made treatment decisions, consulted with MD (OC/DxMx | | Disease control: HbA1c
| Control group: no intervention/usual care | | Control: 8.5 ± 1.6→8.1 ± 1.6
| | | Intervention: 8.4 ± 1.4→8.2 ± 1.5
Coffey, 1995 ^10^ | Intervention group: Patients on managed care plan | | | Patient compliance: % patients compliant with home monitoring
| Control group: Traditional fee-for-service plan | | | Control: 60%→63%
| | | | Intervention: 63%→60%
| | | | Net difference: -6%
Dargis, 1999 ^11^ | Intervention group: Patients received foot care in specialty clinic, special footwear, foot care education (PtE, OC/team) | | Other outcomes: recurrent foot ulcers, amputations
| Control group: one time foot consult with education/advice
de Sonnaville, 1997 ^12^ | Intervention group: Diabetes support service provides GP with consult of podiatrist, diabetologist, and diabetes nurse educator; lab measurements at patient home; retinal camera (PtE, SMx, FR, OC/team) | | Disease control 1: HbA1c
| Control group: no intervention/usual care | | Control: 7.6 ± 1.9→7.6 ± 1.5
| | | Intervention: 7.5 ± 1.7→7.0 ± 1.3
| | | Disease control 2: SBP
| | | Control: 158.2 ± 23.5→ 155.3 ± 22.9
| | | Intervention: 147.2 ± 21.7→ 147.7 ± 23.5
| | | Disease control 2: DBP
| | | Control: 88.9 ± 11.7→ 85.3 ± 11.4
| | | Intervention: 87.7 ± 10.4→ 83.0 ± 12.6
| | | Other outcomes: fasting blood glucose, BMI, total chol, HDL-chol, triglycerides, % smokers
Deeb, 1988 ^13^ | Intervention group: Providers attended diabetes education seminars, had quarterly consults with outside leaders, received printed education modules (PvE, OC/team) | Adherence measure: % patients with BP measured in past year
| Control group: no intervention/usual care | Control: 99%→99%
| | Intervention: 100%→100%
| | Net difference: 0%
| | Adherence measure: % patients with lower-extremity exam in past year
| | Control: 27%→41%
| | Intervention: 66%→94%
| | Net difference: -6%
| | Other outcomes: % patients with urinalaysis, lower-extremity history, referral for retinopathy exam, retinopathy history, and retinopathy exam in past year
Feder, 1995 ^14^ | Intervention group: Diabetes care guidelines introduced, followed by provider audit and feedback as follow-up (PvE, Aud) | Adherence measure: % patients with HbA1c record
| Control group: Providers received guidelines on asthma, not diabetes | Control: 20.6%→30%
| | Intervention: 24.8%→48.1%
| | Net difference: +13.9%
| | Adherence measure: % patients with BP record
| | Control: 66.1%→58.3%
| | Intervention: 69%→79.5%
| | Net difference: +18.3%
| | Adherence measure: % patients with foot exam record
| | Control: 28.3%→27.2%
| | Intervention: 31.4%→51.8%
| | Net difference: +21.5%
| | Adherence measure: % patients with funduscopy record
| | Control: 19.4%→20%
| | Intervention: 20.5%→38.1%
| | Net difference: +17%
| | Other outcomes: % patients with record of blood glucose and weight
Franz, 1995 ^15^ | Comparison 1 | | Disease control: HbA1c
| Intervention group: Patients received diet therapy with dietitian who made recommendations to PCP on medical therapy (PtE, SMx, OC/team) | | Control: 8.3 ± 1.7→8.1 ± 1.7
| Control group: Patients had one meeting with dietitian to discuss diet goals and advice | | Intervention: 8.1 ± 1.6→7.7 ± 1.2
| Comparison 2 | | Disease control: HbA1c
| Intervention group: Patients received diet therapy with dietitian who made recommendations to PCP on medical therapy (PtE, SMx, OC/team) | | Control: 8.2 ± 2.2→6.8 ± 1.3
| Control group: Patients had one meeting with dietitian to discuss diet goals and advice | | Intervention: 8.8 ± 1.9→6.8 ± 1.0
Frijling, 2002 ^16^ | Intervention group: Providers received didactic education and audit and feedback to improve compliance with care guidelines (PvE, Aud) | Adherence measure: % patients with BP record in last year
| Control group: no intervention/usual care | Control: 89%→92%
| | Intervention: 91%→94%
| | Net difference: -1%
| | Adherence measure: % patients with foot exam record in last year
| | Control: 30%→39%
| | Intervention: 24%→43%
| | Net difference: +10%
| | Adherence measure: % patients with eye exam record in last year
| | Control: 69%→67%
| | Intervention: 61%→70%
| | Net difference: +11%
| | Other outcomes: % patients with discussion of body weight control
Gaede, 2003 ^17,^ ^18^ * | Intervention group: Intensive treatment with stepwise implementation of behaviour modification and pharmacologic therapy, dietary and exercise counselling (PtE, OC/DxMx) | | Disease control 1: HbA1c (mean and SE)
| Control group: All patients received individual diabetic dietary advice | | Control: 8.8 ± 1.7→9.0 ± NR
| | | Intervention: 8.4 ± 1.6→7.8 ± NR
| | | Disease control 2: SBP
| | | Control: 149 ± 19→ 146 ± NR
| | | Intervention: 146 ± 20→ 132 ± NR
| | | Disease control 2: DBP
| | | Control: 86 ± 11→ 78 ± NR
| | | Intervention: 85 ± 10→ 73 ± NR
| | | Other outcomes: urinary AER, triglycerides, total cholesterol, GFR
Ginsberg, 1996 ^19^ | Intervention group: Providers trained in Staged Diabetes Management (benchmarking, flowcharts for decision-making, evaluation, feedback to community); patients received education (PtE, PvE) | | Disease control 1: HbA1c
| Control group: no intervention/usual care | | Control: 10.3 ± 2.1→10.4 ± 2.1
| | | Intervention: 10.2 ± 2.8→8.8 ± 0.7
Glasgow, 1996 ^20^ | Intervention group: Brief, computer-based assessment of dietary compliance. Patients received dietary advice, one-on-one counselling, a video and 2 follow-up calls (PtE, SMx, OC/team) | | Disease control: HbA1c
| Control group: no intervention/usual care | | Control: 7.9 ± NR→7.7 ± NR
| | | Intervention: 7.8 ± NR → 7.6 ± NR
| | | Other outcomes: serum blood glucose
Groeneveld, 2001 ^21^ | Intervention group: Patients followed-up with structured diabetes care service including education, testing and advice to PCPs on drug therapy (PtE, FR, OC/DxMx) | | Disease control 1: HbA1c
| Control group: no intervention/usual care | | Control: 7.5 ± 1.8 (post)
| | | Intervention: 7.1 ± 1.2 (post)
| | | Disease control 2: SBP
| | | Control: 149 ± 24→ 143 ± 21
| | | Intervention: 137 ± 21→ 135 ± 18
| | | Disease control 2: DBP
| | | Control: 86 ± 9.7→ 82 ± 9
| | | Intervention: 91 ± 9→ 90 ± 8
| | | Other outcomes: serum blood glucose, total cholesterol, weight, creatinine
Hartmann, 1995 ^22^ | Intervention group: Providers participated in a series of structured peer-review groups focused on diabetes patient records, didactic education and role-play (PvE, Aud) | Adherence measure: % patients with at least one HbA1c record per quarter | | Patient compliance: % patients with documentation of glucose self-mx at least once per quarter
| Control group: Providers had same type of group session only once | Control: 24.4%→32.3% | | Control: 21.3%→17.1%
| | Intervention: 27.6%→26.8% | | Intervention: 7.9%→11.3%
| | Net difference: -8.7% | | Net difference: +7.6%
| | Adherence measure: % patients with record of fundoscopy and foot exam with tuning fork
| | Control: 1.2%→0.6%
| | Intervention: 20.5%→20.5%
| | Net difference: +0.6%
| | Adherence measure: % patients with record of fundoscopy at least once per year
| | Control: 5.5%→13.4%
| | Intervention: 8.4%→32.2%
| | Net difference: +15.9%
| | Other outcomes: % patients with pallaesthesia at least once per year, % patients with documentation of triglycerides, HDL-C and total chol, weight and BP, albumin, serum creatinine at least once per year, blood glucose at least once per quarter
Hayes, 1984 ^23^ | Intervention group: Patients received care from a GP instead of a diabetes specialist clinic, GPs received printed care guidelines (PvE, OC/team) | | Disease control: HbA1c
| Control group: no intervention/usual care (diabetes specialist clinic) | | Control: 9.5 ± 1.77 (post)
| | | Intervention: 10.4 ± 1.73 (post)
Hetlevik, 2000 ^24^ | Intervention group: Computerized support system provided physician with treatment, test, and referral recommendations; providers received feedback of missing tests at 6 month intervals (PvR, Aud) | Adherence measure: % patients with record of HbA1c during study period | Disease control 1: HbA1c
| Control group: no intervention/usual care | Control: 77.6%→81.2% | Control: 8.2 ± 1.8→ 7.9 ± 1.6
| | Intervention: 72.5%→79.5% | Intervention: 8.2 ± 1.8→ 7.8 ± 1.6
| | Net difference: +3.4%
| | Adherence measure: % patients with record of BP during study period | Disease control 2: SBP
| | Control: 77.4%→81.5% | Control: 151.7 ± 21.3→ 152.7 ± 19
| | Intervention: 78.2%→81.3% | Intervention: 152.5 ± 21.6→ 151.5 ± 22.1
| | Net difference: -1%
| | Other outcomes: % patients with record of cholesterol during study period | Disease control 3: DBP
| | | Control: 85.1 ± 10.1→ 85.3 ± 9.9
| | | Intervention: 84.5 ± 10→ 82.8 ± 10.6
Hirsch, 2002 ^25^ | Intervention group: Provider intervention: reminders for tests, diabetes management guidelines, didactic teaching, feedback of HbA1c levels, pharmacist case management, access to endocrinologist (PvE, Aud, OC/DxMx, team) | | Disease control 1: HbA1c
| Control group: Providers received reminders to test HbA1c | | Control: 7.57 ± NR→ 8.2 ± NR
| | | Intervention: 7.64 ± NR→ 7.56 ± NR
| | | Disease control 2: SBP
| | | Control: 134 ± NR→ 137.1 ± NR
| | | Intervention: 135 ± NR→ 133.8 ± NR
| | | Disease control 3: DBP
| | | Control: 80 ± NR→ 79.19 ± NR
| | | Intervention: 79 ± NR→ 75.21 ± NR
Hoskins, 1993 ^26^ | Comparison 1 | Adherence measure: % HbA1c results received from GP out of number of know GP attendances | Disease control 1: HbA1c | Patient compliance: % patients attended visit 3 (out of 3) to their GP during study period
| Intervention group: GP received one time letter requesting adherence to recommended management protocol, and measurement of HbA1c, BP, weight (OC/other) | Control: 98.4% post-intervention | Control: 8.9 ± 2.5→ 7.3 ± 1.6 | Control: 53%
| Control group: All patients received 3–6 mo education before intervention. | Intervention: 45.6 % post-intervention | Intervention: 8.4 ± 2.6→ 6.9 ± 1.3 | Intervention: 35%
| | Adherence measure: % weight measurements received from GP out of number of know GP attendances | Disease control 2: SBP
| | Control: 98.3% post-intervention | Control: 150 ± 23→ 133 ± 19
| | Intervention: 70.6 % post-intervention | Intervention: 148 ± 23→ 136 ± 14
| | Adherence measure: % BP measurements received from GP out of number of know GP attendances | Disease control 3: DBP
| | Control: 92.7% post-intervention | Control: 90 ± 13→ 81 ± 13
| | Intervention: 89.7 % post-intervention | Intervention: 90 ± 15→ 80 ± 11
| | | Other outcomes: weight
| Comparison 2 | Adherence measure: % HbA1c results received from GP out of number of know GP attendances | Disease control 1: HbA1c | Patient compliance: % patients attended visit 3 (out of 3) to their GP during study period
| Intervention group: Shared care between patient, GP, clinic. Nurse liaised btw patient and GP, reminded GP of measurements. Patient received copy of management protocol (SMx, PtR, PvR, OC/team/other) | Control: 98.4% post-intervention | Control: 8.9 ± 2.5→ 7.3 ± 1.6 | Control: 53%
| Control group: All patients received 3–6 mo education before intervention. | Intervention: 66 % post-intervention | Intervention: 8.5 ± 2.2→ 6.6 ± 1.6 | Intervention: 72%
| | Adherence measure: % weight measurements received from GP out of number of know GP attendances | Disease control 2: SBP
| | Control: 98.3% post-intervention | Control: 150 ± 23→ 133 ± 19
| | Intervention: 93.5 % post-intervention | Intervention: 145 ± 24→ 130 ± 25
| | Adherence measure: % BP measurements received from GP out of number of know GP attendances | Disease control 3: DBP
| | Control: 92.7% post-intervention | Control: 90 ± 13→ 81 ± 13
| | Intervention: 94.8 % post-intervention | Intervention: 88 ± 13→ 81 ± 11
| | | Other outcomes: weight
Hurwitz, 1993 ^27^ | Intervention group: Patients received computer-generated reminders to get blood and urine tests done. Results relayed to providers, appointments made as necessary (PtR, FR) | | Disease control: HbA1c
| Control group: usual care with specialist | | Control: 10.3 ± 2.3→ 10.6 ± 2.5
| | | Intervention: 10.4 ± 2.5→ 10.3 ± 2.3
| | | Other outcomes: serum blood glucose, % mortality
Jaber, 1996 ^28^ | Intervention group: Pharmacist was responsible for medication adjustments and provided education, dietary and exercise counselling (PtE, Oc/team) | | Disease control: HbA1c
| Control group: no intervention/usual care | | Control: 12.2 ± 3.5→ 12.1 ± 3.7
| | | Intervention: 11.5 ± 2.9→ 9.2 ± 2.1
| | | Other outcomes: serum blood glucose
Kiefe, 2001 ^29^ | Intervention group: Providers had QI education and audit and feedback, as well as “achievable benchmarks” for specific processes of care (Aud) | Adherence measure: % patients with at least one HbA1c in 18-month period
| Control group: Provider education and audit and feedback | Control: 35%→65%
| | Intervention: 31%→70%
| | Net difference: +9%
| | Adherence measure: % patients with at least one foot exam in 18-month period
| | Control: 32%→45%
| | Intervention: 46%→61%
| | Net difference: +2%
Kinmonth, 1998 ^30^ | Intervention group: Providers received training in patient-centered care as well as materials to give to patients (PtE, PvE) | | Disease control 1: HbA1c
| Control group: Limited training on use of guidelines and patient materials | | Control: 7.17 ± NR (post)
| | | Intervention: 7.07 ± NR (post)
| | | Disease control 2: SBP
| | | Control: 141.5 ± NR→ 142.8 ± NR
| | | Intervention: 144.1 ± NR→ 144.3 ± NR
| | | Disease control 3: DBP
| | | Control: 83.7 ± NR→ 87.2 ± NR
| | | Intervention: 85.5 ± NR→ 89 ± NR
| | | Other outcomes: total cholesterol, BMI, % smoking
Kogan, 2003 ^31^ | Intervention group: Residents received report card of individual and group disease management performance and brief discussion with faculty (Aud) | Other outcomes: % overall diabetes management (pneumovax, flu shot, creatinine, microalbumin, appropriate use of ACE-inhibitors, dilated eye exam, foot exam, lipid screening, lipid management, HbA1c, diet, exercise) recorded in chart
| Control group: no intervention/usual care
Legorreta, 1996 ^32^ | Comparison 1 | | Disease control: HbA1c
| Intervention group: Nurse case managed patients using protocols for management. Computer information system generated reminders and algorithms for medication adjustment. Diabetologist available for consult (PtR, PvE, OC/DxMx/medrcrd/other) | | Control: 8.3 ± 2.6→ 9.1 ± NR
| Control group: no intervention/usual care | | Intervention: 8.9 ± 2.1→ 6.9 ± NR
| | | Other outcomes: LDL-cholesterol
| Comparison 2 | | Disease control: HbA1c
| Intervention group: Nurse case managed patients using protocols for management. Computer information system generated reminders and algorithms for medication adjustment. Diabetologist available for consult (PtR, PvE, OC/DxMx/medrcrd/other) | | Control: 8.6 ± 2.0→ 8.4 ± NR
| Control group: no intervention/usual care | | Intervention: 10.3 ± 2.5→ 9.0 ± NR
| | | Other outcomes: LDL-cholesterol
Levetan, 2002 ^33^ | Intervention group: Patients received a wall poster and wallet card containing current lab values and goals, as well as postcards with reminders. Providers received lab values as well (PtE, SMx, PtR, PvR, FR) | | Disease control 1: HbA1c
| Control group: All patients had finished 3 month diabetes education before enrolment in study | | Control: 8.39 ± 2.03→ 7.79 ± 1.91
| | | Intervention: 8.85 ± 2.48→ 7.78 ± 2.22
| | | Other outcomes: % patients with HbA1c in range, HDL-chol, LDL-chol
Lim, 2002 ^34^ | Intervention group: Case management with PCP, case manager, podiatrist, dietitian. Patients received education and reminders. Providers received reminders for testing/referral (PtE, PvR, OC/DxMx) | | Disease control 1: HbA1c
| Control group: no intervention/usual care | | Control: 8.28 ± 1.94→ 8.28 ± 1.69
| | | Intervention: 9.81 ± 2.22→ 7.82 ± 1.75
| | | Disease control 2: SBP
| | | Control: 138.9 ± 19.3→ 136.8 ± 18.5
| | | Intervention: 142.1 ± 16.4→ 134.2 ± 10.1
| | | Disease control 3: DBP
| | | Control: 80.8 ± 8.9→ 79.1 ± 8.41
| | | Intervention: 82.8 ± 10.3→ 80.5 ± 7.8
| | | Other outcomes: % patients with HbA1c in range, % patients with BP in range
Litzelman, 1993 ^35^ | Intervention group: Patients received education on foot care and reminders by phone and mail to continue foot care. Provider received reminders in chart to educate patient and perform foot care (PtE, PtR, PvE, PvR) | | Other outcomes: % patients with serious foot lesions
| Control group: no intervention/usual care
Lobach, 1997 ^36^ | Intervention group: Computerized system of guidelines provided physicians with reminders for tests/referrals (PvR) | Adherence measure: % provider compliance with chronic glycemia monitoring
| Control group: no intervention/usual care | Control: 52.8% (post)
| | Intervention: 57.4% (post)
| | Adherence measure: % provider compliance with cholesterol level determination
| | Control: 13.4% (post)
| | Intervention: 43.7% (post)
| | Adherence measure: % provider compliance with foot exam
| | Control: 30% (post)
| | Intervention: 55.6% (post)
| | Adherence measure: % provider compliance with opthalmologic exam
| | Control: 3.2% (post)
| | Intervention: 18.8% (post)
| | Other outcomes: % provider compliance with urine protein determination
Mazzuca, 1986 ^37^ | Comparison 1 | | Disease control 1: HbA1c
| Intervention group: Providers had one didactic session with three problem-oriented follow-up sessions, distribution of guidelines, access to specialist, computer-generated guideline reminders (PvE, PvR, Aud) | | Control: 10.19 ± NR→ 10.74 ± NR
| Control group: no intervention/usual care | | Intervention: 10.51 ± NR→ 10.65 ± NR
| | | Disease control 2: SBP
| | | Control: 137.2 ± NR→ 144.9 ± NR
| | | Intervention: 142.5 ± NR→ 146.4 ± NR
| | | Disease control 3: DBP
| | | Control: 81.4 ± NR→ 85.2 ± NR
| | | Intervention: 83.1± NR→ 83.4 ± NR
| | | Other outcomes: serum creatinine, fasting blood glucose
| Comparison 2 | | Disease control 1: HbA1c
| Intervention group: Providers had one didactic session with three problem-oriented follow-up sessions, distribution of guidelines, access to specialist, computer-generated guideline reminders; patients had didactic sessions and dietary education (PtE, PtR, PvE, PvR, Aud) | | Control: 10.19 ± NR→ 10.74 ± NR
| Control group: no intervention/usual care | | Intervention: 11.34 ± NR→ 10.42 ± NR
| | | Disease control 2: SBP
| | | Control: 137.2 ± NR→ 144.9 ± NR
| | | Intervention: 140.4 ± NR→ 145 ± NR
| | | Disease control 3: DBP
| | | Control: 81.4 ± NR→ 85.2 ± NR
| | | Intervention: 81.8± NR→ 81.3 ± NR
| | | Other outcomes: serum creatinine, fasting blood glucose
McDermott, 2001 ^38^ | Intervention group: Visit to clinic by outreach team (diabetologist, nutritionist, podiatrist, diabetes healthcare worker), reminder and recall system (PtR, PvE, PvR, Aud, OC/medrcrd) | Adherence measure: % patients with HbA1c check in past 6 mo. | Other outcomes: % patients with HbA1c in range, % patients with BP in range
| Control group: Outreach team visits, audit of past clinician adherence guidelines | Control: 60%→62%
| | Intervention: 70%→73%
| | Net difference: +1%
| | Adherence measure: % patients with BP check in past 6 mo.
| | Control: 64%→57%
| | Intervention: 76%→65%
| | Net difference: -4%
| | Adherence measure: % patients with foot check in past year
| | Control: 52%→55%
| | Intervention: 60%→72%
| | Net difference: +9%
| | Adherence measure: % patients with opthalmologist check in past year
| | Control: 18%→22%
| | Intervention: 21%→25%
| | Net difference: 0%
| | Other outcomes: % patients with serum creatinine past yr, lipids past yr, urinary ACR past yr
Meigs, 2003 ^39^ | Intervention group: Providers given access to web-based system of clinical information and care recommendations for individual patients to be used during visit (PvE, PvR) | Adherence measure: % patients with at least one HbA1c in past year | Disease control 1: HbA1c (mean and SE)
| Control group: no intervention/usual care | Control: 88%→87% | Control: 8.1 ± 0.1→ 8.24 ± NR
| | Intervention: 86%→87.6% | Intervention: 8.4 ± 0.1→ 8.17 ± NR
| | Net difference: -2.6%
| | Adherence measure: % patients with at least one BP in past year | Disease control 2: SBP
| | Control: 98.6%→97.2% | Control: 136.9± 1.2→ 134.7± NR
| | Intervention: 97.4%→98.4% | Intervention: 138.1 ± 1.2→ 138.9 ± NR
| | Net difference: +0.4%
| | Adherence measure: % patients with at least one foot exam in past year | Disease control 3: DBP
| | Control: 82.1%→81.4% | Control: 76.4 ± 0.6→ 75.6 ± NR
| | Intervention: 65.5%→75.3% | Intervention: 78.3± 0.6→ 79.1± NR
| | Net difference: +10.5%
| | Adherence measure: % patients with at least one eye exam in past year | Other outcomes: % patients with HbA1c and BP in range, LDL-chol
| | Control: 41.2%→42.9%
| | Intervention: 29.3%→34.8%
| | Net difference: +3.8%
| | Other outcomes: % patients with at least on LDL-chol in past year
O'Connor, 1996 ^40^ | Intervention group: Continuous quality improvement program of: audit and feedback, patient education by RN, nurse responsibility for care of poorly controlled diabetics (PtE, Aud, OC/DxMx) | | Disease control: HbA1c (mean ± SE)
| Control group: no intervention/usual care | | Control: 8.4 ± 0.19→ 8.8 ± 0.17
| | | Intervention: 8.9 ± 0.22→ 7.9 ± 0.17
| | | Other outcomes: % patients with HbA1c in range
Oh, 2003 ^41^ | Intervention group: Patients received regular telephone calls to monitor glucose and diet and make medication adjustments. Changes and data relayed to MD (PtE, FR) | | Disease control: HbA1c
| Control group: no intervention, usual care | | Control: 8.4 ± 1.0→ 9.0 ± 1.2
| | | Intervention: 8.9 ± 1.2→ 7.7 ± 1.0
| | | Other outcomes: FBG, 2-hr post prandial BG, BMI
Olivarius, 2001 ^42^ | Intervention group: Providers prompted to see patients every 3 months and follow care guidelines, received annual guideline seminar and audit and feedback of individual patient status (PtE, PvE, PvR, Aud) | | Other outcomes: % patients with HbA1c and BP in range, MI, stroke, amputation, retinopathy, neuropathy, angina pectoris, microalbuminuria, smoking; mean/median total cholesterol, triglycerides, serum blood glucose, serum creatinine
| Control group: no intervention/usual care
Ovhed, 2000 ^43^ | Intervention group: Patients care for primary by RN using care guidelines (OC/team/other) | Adherence measure: % patients with record of HbA1c during study year | | Patient compliance: % patients with record of urine and blood glucose self-measurement during study year
| Control group: no intervention/usual care | Control: 36% post-intervention
| | Intervention: 97% post-intervention
| | Adherence measures (HTN/CAD): % patients with record of body weight, cholesterol, TG, BP in study year
| | Adherence measure: % patients with fundus photo during study year
| | Control: 47%
| | Intervention: 73%
| | Other outcome: % patients with FBG record during study year
Palmer, 1985 ^44^ | Intervention group: Provider quality assurance training and audit and feedback of selected cases (Aud, OC/other) | Other outcomes: % follow-up of abnormal glucose levels
| Control group: no intervention/usual care
Piette, 2000 ^45^ | Intervention group: Automated telephone system for patient reporting of blood glucose, symptoms, self-care behaviours. Results relayed from nurse to physician, nurse follow-up to patient by phone (PtE, SMx, FR, OC/team | | Disease control 1: HbA1c
| Control group: no intervention/usual care | | Control: 8.6 ± 1.8→ 8.3 ± 1.9
| | | Intervention: 8.8 ± 1.8→ 8.2 ± 1.9
| | | Other outcomes: % patients with HbA1c in a range, serum glucose
Piette, 2001 ^46^ | Intervention group: Automated telephone system for patient reporting of blood glucose, symptoms, self-care behaviours. Results relayed from nurse to physician, nurse follow-up to patient by phone (PtE, SMx, PtR, FR, OC/team | | Disease control 1: HbA1c
| Control group: no intervention/usual care | | Control: 8.1 ± 1.7→ 8.2 ± 0.1 (SEM)
| | | Intervention: 8.2 ± 1.7→ 8.1 ± 0.1 (SEM)
| | | Other outcomes: % patients with HbA1c in a range, serum glucose
Pouwer, 2001 ^47^ | Intervention group: Patients monitored twice by diabetes nurse specialist and survey for psychological wellbeing, referred to psychologist if appropriate (OC/other) | | Disease control: HbA1c
| Control group: Patients had two meetings with diabetes nurse specialist. | | Control: 7.8 ± NR→ 7.7 ± NR
| | | Intervention: 7.8 ± NR→ 7.7 ± NR
Reed, 2001 ^48^ | Intervention group: 3 diabetes care clinics created, used to introduce care guidelines; patients given education and clinical data cards to bring to appointments; provider education and access to hospital-based specialists (PtE, PvE, FR, OC/team/medrcrd) | | Disease control 1: SBP
| Control group: no intervention/usual care | | Control: 133.7 ± 19→ 131.3 ± 16.6
| | | Intervention: 129.2 ± 18.8→ 126.5 ± 16.4
| | | Disease control 2: DBP
| | | Control: 82.6 ± 9.5→ 81.1 ± 9.1
| | | Intervention: 79.4 ± 8.6→ 80.9 ± 8.7
Renders, 2001 ^49^ | Intervention group: Providers received clinical guideline education, audit and feedback and relay of data from central monitoring visit (PvE, FR, Aud) | Adherence measure: % patients with HbA1c at least once per year | Other outcomes: % patients with HbA1c and BP in range, total cholesterol, HDL-cholesterol, triglycerides, BMI
| Control group: annual visit with resulting data sent to GPs | Control: 15.6%→29.3%
| | Intervention: 34.9%→75.5%
| | Net difference: +26.9%
| | Other outcomes: % patients with at least one urine albumin, serum creatinine, triglycerides, total cholesterol, HDL-chol, blood pressure measurements per year, % patients with weight measurements and diabetes visits 4 per year
Ronnemaa, 1997 ^50^ | Intervention group: Patients received foot education and primary prevention from podiatrist (PtE, OC/team) | | Other outcomes: % patients with: callosities in calcaneal region and other regions, corns, ingrown toenails, other nail disorders, inability to spread out toes, inability to flex toes | Patient compliance: foot self-care score (out of 12)
| Control group: Patients received written information on foot care and preventive practices | | | Control: 5.3 ± 2.6→ 6.0 ± 2.5
| | | | Intervention: 5.4 ± 2.8→ 7.0 ± 3.2
Sadur, 1999 ^51^ | Intervention group: Multidisciplinary care team of diabetologist, RN educator, pharmacist, dietitian, behaviourist. Patients received education, foot care, counselling, feedback (PtE, PtR, OC/DxMx/team) | | Disease control: HbA1c | Patient compliance: % patients monitoring BG at home
| Control group: no intervention/usual care | | Control: 9.55 ± NR→ 9.33 ± NR | Control: 93.4%→93.6%
| | | Intervention: 9.48 ± NR→ 8.18 ± NR | Intervention: 90%→97.5%
Smith, 1998 ^52^ | Intervention group: Physicians entered clinical data into electronic system during patient visit (OC/medrcrd) | Adherence measure: % patients with 4 HbA1c measurements per yr | Disease control 1: HbA1c
| Control group: no intervention/usual care | Control: 51.2% post | Control: 10.2 ± 1.9 post
| | Intervention: 76.9% post | Intervention: 9.7 ± 1.7 post
| | Adherence measure: % patients with dilated eye exam in past yr | Disease control 2: SBP
| | Control: 65.1% post | Control: 140.9 ± 19.6 post
| | Intervention: 64.1% post | Intervention: 138.3 ± 16.9 post
| | Other outcomes: % patients with measurement of urinary microalbumin, lipid profile in past year; % patients with diabetes self-mx and diet education; % smoking patients with advice to quit | Disease control 2: DBP
| | | Control: 93.6 ± 25 post
| | | Intervention: 80.6 ± 9.6
Stroebel, 2002 ^53^ | Comparison 1 | Adherence measure: % patients with HbA1c in 6 months | Disease control: HbA1c (mean ± SE)
| Intervention group: 20-minute physician meeting every 2 months to remind to use Hot Lists of patients needing test (OC/other) | Control: 77%→74% | Control: 8.1 ± 1.8→ 8.0 ± 1.8
| Control group: Academic detailing and “hot list” of patients not in compliance | Intervention: 74%→76% | Intervention: 8.3 ± 2→ 8.2 ± 2
| | Net difference: 5%
| | Other outcomes: % patients with LDL-chol in last year | Other outcomes: % patients with HbA1c and BP in a range, LDL-Chol
| Comparison 1 | Adherence measure: % patients with HbA1c in 6 months | Disease control: HbA1c (mean ± SE)
| Intervention group: 20-minute physician meeting every 2 months to remind to use Hot Lists of patients needing test and reminders to patients on Hot Lists to make appointments (PtR, OC/other) | Control: 77%→74% | Control: 8.1 ± 1.8→ 8.0 ± 1.8
| Control group: Academic detailing and “hot list” of patients not in compliance | Intervention: 79%→78% | Intervention: 8.1 ± 2→ 7.9 ± 1.8
| | Net difference: 2%
| | Other outcomes: % patients with LDL-chol in last year | Other outcomes: % patients with HbA1c and BP in a range, LDL-Chol
Thompson, 1999 ^54^ | Intervention group: Patients received 3x weekly calls from RN who adjusted insulin and reviewed with MD (PtE, FR, OC/team) | | Disease control: HbA1c
| Control group: no intervention/usual care | | Control: 9.4 ± 0.8→ 8.9 ± 1.0
| | | Intervention: 9.6 ± 1.0→ 7.8 ± 0.8
Vaughan, 1996 ^55^ | Intervention group: Patients were treated by RN using paper algorithms for medication adjustment (OC/team) | Adherence measure: % patients with HbA1c performed | Other outcomes: % patients with HbA1c in a range
| Control group: no intervention/usual care | Control: 79% post
| | Intervention: 100% post
Wagner, 2001 ^56^ | Intervention group: Patients received care (MD visit, RN visit, pharmacist visit, group education) at chronic care clinic (PtE, SMx, OC/team) | Adherence measure: % patients with foot exam in past year | Disease control: HbA1c
| Control group: no intervention/usual care | Control: 80.8% post | Control: 7.4 ± NR→ 7.9 ± NR
| | Intervention: 87.7% post | Intervention: 7.5 ± NR→ 7.9 ± NR
| | Adherence measure: % patients with retinal eye exam in past year | Other outcomes: total cholesterol
| | Control: 62.2%→63.5%
| | Intervention: 60.6%→67.9%
| | Net difference: +6%
| | Other outcomes: % patients with microalbumin test in past year
Walker, 2001 ^57^ | Comparison 1 | Adherence measure: % patients with at least one record of HbA1c
| Intervention group: Providers had one time problem-based learning education program, printed guidelines, follow-up (PvE) | Control: 44%→63%
| Control group: Clinic was sent printed care guidelines with no follow-up | Intervention: 53%→73%
| | Net difference: +1%
| | Adherence measure: % patients with document of foot exam
| | Control: 22%→50%
| | Intervention: 53%→76%
| | Net difference: -5%
| | Adherence measure: % patients with documented DFE or referral for DFE
| | Control: 37%→33%
| | Intervention: 21%→38%
| | Net difference: +21%
| | Other outcomes: % patients with at least one serum creatinine record
| Comparison 2 | Adherence measure: % patients with at least one record of HbA1c
| Intervention group: Providers had one time problem-based learning education program, printed guidelines, follow-up; clinic received printed patient guides to disseminate (PtE, PvE) | Control: 44%→63%
| Control group: Clinic was sent printed care guidelines with no follow-up | Intervention: 40%→44%
| | Net difference: -15%
| | Adherence measure: % patients with document of foot exam
| | Control: 22%→50%
| | Intervention: 46%→58%
| | Net difference: -16%
| | Adherence measure: % patients with documented DFE or referral for DFE
| | Control: 37%→33%
| | Intervention: 19%→55%
| | Net difference: +40%
| | Other outcomes: % patients with at least one serum creatinine record
Ward, 1996 ^58^ | Comparison 1 | Adherence measure: % patients with one HbA1c per 8 months
| Intervention group: Providers received feedback of their care records compared to the whole group and checklists of guidelines; providers had interview with a GP regarding care guidelines (PvE, Aud) | Control: 46.7%→40.7%
| Control group: Providers received feedback of their care records compared to the whole group and checklists of guidelines | Intervention: 36.9%→54.6%
| | Net difference: +23.7%
| | Adherence measure: % patients with record of eye exam or referral to opthalmologist annually
| | Control: 29.6%→31.1%
| | Intervention: 23.1%→42.3%
| | Net difference: +17.7%
| | Other outcomes: % patients with record of urine and blood glucose (2 per 8 mo); urine protein, urine nitrite, creatinine, total cholesterol, triglycerides (1 per 8 mo); blood pressure, weight, foot reflex exam, feet pulses, feet sensation, nails (annually); alcohol inquiry and advice, diet, exercise, smoking, vaginitis/impotence advice
| Comparison 2 | Adherence measure: % patients with one HbA1c per 8 months
| Intervention group: Providers received feedback of their care records compared to the whole group and checklists of guidelines; providers had interview with a nurse regarding care guidelines (PvE, Aud) | Control: 46.7%→40.7%
| Control group: Providers received feedback of their care records compared to the whole group and checklists of guidelines | Intervention: 28.9%→44.6%
| | Net difference: +21.7%
| | Adherence measure: % patients with record of eye exam or referral to opthalmologist annually
| | Control: 29.6%→31.1%
| | Intervention: 19.8%→40.5%
| | Net difference: +19.2%
| | Other outcomes: % patients with record of urine and blood glucose (2 per 8 mo); urine protein, urine nitrite, creatinine, total cholesterol, triglycerides (1 per 8 mo); blood pressure, weight, foot reflex exam, feet pulses, feet sensation, nails (annually); alcohol inquiry and advice, diet, exercise, smoking, vaginitis/impotence advice
Weinberger, 1995 ^59^ | Intervention group: Nurse performed patient education, medication counselling, liaison to MD by telephone contact with patients (PtE, SMx, PtR, FR, OC/DxMx) | | Disease control: HbA1c
| Control group: no intervention/usual care | | Control: 10.7 ± 3.4→ 11.1 ± 2.4
| | | Intervention: 10.7 ± 3.3→ 10.5 ± 2.7
| | | Other outcomes: serum blood glucose, total cholesterol, LDL-C, HDL-C, triglycerides

* Results reported come from both articles.

Table E2 Main results for blood pressure

Setting | Study period | Study Design* | QI strategies employed ˆ | Systolic blood pressure results
| (duration) | (Number of Patients)
28 general practices | 1989-1995 | CBA | Patient Ed, Self-Mx, Facil relay, Org change | Control: 158.2±23.5 → 155.3±22.9
(Netherlands) ^12^ | (6 years) | (505, 28 providers) | | Intervention: 147.2±21.7 → 147.7±23.5
Diabetes clinic | 1993-2001 | RCT | Patient Ed, Org change | Control: 149±19 → 146±NR
(Denmark) ^17,^ ^18^ ^†^ | (9 years) | (160) | | Intervention: 146±20 → 132±NR
Specialized diabetic service | --- | RCT | Patient Ed, Facil relay, Org change | Control: 149±24 → 143±21
(Netherlands) ^21^ | (1 year) | (246, 15 practices) | | Intervention: 137±21 → 135±18
29 general practices | --- | RCT | Prvdr Remind, Audit & Fdbck | Control: 151.7±21.3 → 152.7±19
(Norway) ^24^ | (21 months) | (1034, 17 practices) | | Intervention: 152.5±21.6 → 151.5±22.1
U. of Washington Family Medical Center | 1998-1999 | RCT | Prvdr Ed, Audit & Fdbck, Org change | Control: 134±NR → 137.1±NR
(Seattle, WA) ^25^ | (14 months) | (109, 2 firms) | | Intervention: 135±NR → 133.8±NR
Royal Prince Alfred Hospital Diabetes Clinic | --- | RCT | Org change | Control: 150±23 → 133±19
(Australia) ^26^ | (1 year) | (137) | | Intervention: 148±23 → 136±14
Royal Prince Alfred Hospital Diabetes Clinic | --- | RCT | Self-Mx, Pt Remind, Prvdr Remind, Org change | Control: 150±23 → 133±19
(Australia) ^26^ | (1 year) | (134) | | Intervention: 145±24 → 130±25
Cedars Sinai Medical Center | 1994-1995 | RCT | Patient Ed, Prvdr Ed | Control: 141.5±NR → 142.8±NR
(Los Angeles, CA) ^30^ | (1 year) | (360, 43 practice teams) | | Intervention: 144.1±NR → 144.3±NR
Diabetes education program | 1998-1999 | RCT | Patient Ed, Self-Mx, Pt Remind, Prvdr Remind, Facil relay | Control: 143±NR → NR±NR
(unspecified US city) ^33^ | (6 months) | (150) | | Intervention: 142±NR → NR±NR
Choa Chu Kang polyclinic (Singapore) ^34^ | 2000-2001 | CBA | Patient Ed, Prvdr Remind, Org change | Control: 138.9±19.3 → 136.8±18.5
| (7 months) | (211) | | Intervention: 142.1±16.4 → 134.2±10.1
General medicine clinic, Indiana University Medical Center ^37^ | 1978-1982 | RCT | Prvdr Ed, Prvdr Remind, Audit & Fdbck | Control: 137.2±NR → 144.9±NR
| (3 years) | (260, 13 firms) | | Intervention: 142.5±NR → 146.4±NR
General medicine clinic, Indiana University Medical Center ^37^ | 1978-1982 | RCT | Patient Ed, Pt Remind, Prvdr Ed, Prvdr Remind, Audit & Fdbck | Control: 137.2±NR → 144.9±NR
| (3 years) | (273, 14 firms) | | Intervention: 140.4±NR → 145±NR
Hospital-based Adult Medicine Clinic | 1998-1999 | RCT | Prvdr Ed, Prvdr Remind | Control: 136.9±NR → 134.7±NR
(unspecified US city) ^39^ | (1 year) | (598, 2 firms) | | Intervention: 138.1±NR → 138.9±NR
9 primary health centers | --- | CBA | Patient Ed, Prvdr Ed, Facil relay, Org change | Control: 133.7±19 → 131.3±16.6
(United Arab Emirates) ^48^ | (18 months) | (219, 9 practices) | | Intervention: 129.2±18.8 → 126.5±16.4
Sub-specialty diabetes clinic | 1996 | CBA | Org change | Control: NR±NR → 140.9±19.6
(unspecified US city) ^52^ | (3 months) | (82) | | Intervention: NR±NR → 138.3±16.9

* RCT - randomized controlled trial; CBA - controlled before after comparison.

ˆ Pt Remind - patient reminder, Prvdr Remind - provider reminder, Org change - organizational change, Self-Mx — self-management, Facil Relay — facilitated relay of clinical data to providers, Patient Ed — patient education, Prvdr Ed — provider education, Audit & Fdbck — audit and feedback to provider Financial — financial or regulatory intervention

## Appendix E References

1 Ahring KK, Ahring JP, Joyce C, Farid NR. Telephone modem access improves diabetes control in those with insulin-requiring diabetes. Diabetes Care. Aug. 1992;15(8):971-975. SelfMx, FcltdRly:Dz/HbA1c/other. [pmid: 1505329].
2 Albisser AM, Harris RI, Sakkal S, Parson ID, Chao SC. Diabetes intervention in the information age. Med Inform (Lond). Oct–Dec. 1996;21(4):297-316. SelfMx, FcltdRly, OrgChng/medrcrd:clin information\other:Dz/HbA1c/other. [pmid: 9179834].
3 Aubert RE, Herman WH, Waters J, et al. Nurse case management to improve glycemic control in diabetic patients in a health maintenance organization. A randomized, controlled trial. Ann Intern Med. Oct 15. 1998;129(8):605-612. PtEd, FcltdRly, OrgChng/DxMx:Dz/other(HbA1c)(BP), Adhere/other. [pmid: 9786807].
4 Benjamin EM, Schneider MS, Hinchey KT. Implementing practice guidelines for diabetes care using problem-based learning. A prospective controlled trial using firm systems. Diabetes Care. Oct. 1999;22(10):1672-1678. PrvdrEd/workshops/materials:Dz/HbA1c. [pmid: 10526733].
5 Boucher BJ, Claff HR, Edmonson M, et al. A pilot Diabetic Support Service based on family practice attenders: comparison with diabetic clinics in east London. Diabet Med. Sep–Oct. 1987;4(5):480-484. PrvdrEd/workshops, FcltdRly, OrgChng/mdrcrd:clin information\Rmndr:Dz/HbA1c. [pmid: 2959442].
6 Branger PJ, van't Hooft A, van der Wouden JC, Moorman PW, van Bemmel JH. Shared care for diabetes: supporting communication between primary and secondary care. Int J Med Inf. Feb–Mar. 1999;53(23):133-142. FcltdRly, OrgChng/other:clin information\Comm:Dz/HbA1c.
7 Cagliero E, Levina EV, Nathan DM. Immediate feedback of HbA1c levels improves glycemic control in type 1 and insulin-treated type 2 diabetic patients. Diabetes Care. Nov. 1999;22(11):1785-1789. FcltdRly:Dz/HbA1c. [pmid: 10546008].
8 Clancy DE, Brown SB, Magruder KM, Huang P. Group visits in medically and economically disadvantaged patients with type 2 diabetes and their relationships to clinical outcomes. Top Health Inf Manage. Jan–Mar. 2003;24(1):8-14. PtEd, OrgChng/DxMx/team:Adhere/other. [pmid: 12674390].
9 Clifford RM, Batty KT, Davis TME, et al. A randomised controlled trial of a pharmaceutical care programme in high-risk diabetic patients in an outpatient clinic. International Journal of Pharmacy Practice. June. 2002;Vol 10(2):85-90. OrgChng/team:Dz/HbA1c.
10 Coffey E, Moscovice I, Finch M, Christianson JB, Lurie N. Capitated Medicaid and the process of care of elderly hypertensives and diabetics: results from a randomized trial. Am J Med. Jun. 1995;98(6):531-536. Financial:Pat comp. [pmid: 7778569].
11 Dargis V, Pantelejeva O, Jonushaite A, Vileikyte L, Boulton AJ. Benefits of a multidisciplinary approach in the management of recurrent diabetic foot ulceration in Lithuania: a prospective study. Diabetes Care. Sep. 1999;22(9):1428-1431. PtEd, OrgChng/team:Dz/other. [pmid: 10480504].
12 de Sonnaville JJ, Bouma M, Colly LP, Deville W, Wijkel D, Heine RJ. Sustained good glycaemic control in NIDDM patients by implementation of structured care in general practice: 2-year follow-up study. Diabetologia. Nov. 1997;40(11):1334-1340. PtEd, SelfMx, FcltdRly, OrgChng/team:Dz/HbA1c/BP/other. [pmid: 9389427].
13 Deeb LC, Pettijohn FP, Shirah JK, Freeman G. Interventions among primary-care practitioners to improve care for preventable complications of diabetes. Diabetes Care. Mar. 1988;11(3):275-280. PrvdrEd/workshops/materials/outreach, OrgChng/team:Adhere/HTN/footeye/other. [pmid: 3416683].
14 Feder G, Griffiths C, Highton C, Eldridge S, Spence M, Southgate L. Do clinical guidelines introduced with practice based education improve care of asthmatic and diabetic patients? A randomised controlled trial in general practices in east London. BMJ. Dec 2. 1995;311(7018):1473-1478. PrvdrEd/workshops/outreach, AuditFdbck:Adhere/HbA1c/HTN/footeye/other. [pmid: 8520339]. [pmcid: 2543702].
15 Franz MJ, Monk A, Barry B, et al. Effectiveness of medical nutrition therapy provided by dietitians in the management of non-insulin-dependent diabetes mellitus: a randomized, controlled clinical trial. J Am Diet Assoc. 1995/09// 1995;95(9):1009–1017:PtEd, SelfMx, OrgChng/team:Dz/HbA1c
16 Frijling BD, Lobo CM, Hulscher ME, et al. Multifaceted support to improve clinical decision making in diabetes care: a randomized controlled trial in general practice. Diabet Med. Oct. 2002;19(10):836-842. PrvdrEd/workshops/outreach, AuditFdbck:Adhere/HTN/footeye/edu. [pmid: 12358871].
17 Gaede P, Vedel P, Larsen N, Jensen GV, Parving HH, Pedersen O. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. Jan 30. 2003;348(5):383-393. PtEd, OrgChng/DxMx:Dz/HbA1c/BP/other. [pmid: 12556541].
18 Gaede P, Vedel P, Parving HH, Pedersen O. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. Feb 20. 1999;353(9153):617-622. :Diabetes & HTN search. [pmid: 10030326].
19 Ginsberg BH. Preliminary results of a disease state management program or diabetes. J Clin Outcomes Manage. 1996;3(4):45. PtEd, PrvdrEd/materials:clin information\Audit:Dz/HbA1c.
20 Glasgow RE, Toobert DJ, Hampson SE. Effects of a brief office-based intervention to facilitate diabetes dietary self-management. Diabetes Care. Aug. 1996;19(8):835-842. PtEd, SelfMx, OrgChng/team:Dz/HbA1c/other. [pmid: 8842601].
21 Groeneveld Y, Petri H, Hermans J, Springer M, IN. An assessment of structured care assistance in the management of patients with type 2 diabetes in general practice. Scandinavian Journal of Primary Health Care. 2001/// 2001;Vol 19(1):30:PtEd, FcltdRly, OrgChng/DxMx:Dz/HbA1c/BP/other
22 Hartmann, et al. Effects of peer-review groups on physicians' practice. Eur J Gen Pract. 1995;1:107. PrvdrEd/workshops, AuditFdbck:Adhere/HbA1c/HTN/footeye/other, Pat comp.
23 Hayes TM, Harries J. Randomised controlled trial of routine hospital clinic care versus routine general practice care for type II diabetics. Br Med J (Clin Res Ed). Sep 22. 1984;289(6447):728-730. PrvdrEd/materials, OrgChng/team:Dz/HbA1c.
24 Hetlevik I, Holmen J, Kruger O, Kristensen P, Iversen H, Furuseth K. Implementing clinical guidelines in the treatment of diabetes mellitus in general practice. Evaluation of effort, process, and patient outcome related to implementation of a computer-based decision support system. Int J Technol Assess Health Care. Winter. 2000;16(1):210-227. PrvRmndr, AuditFdbck:clin information\Rmndr, CDSS, Audit:Dz/HbA1c/BP, Adhere/HbA1c/HTN/other. [pmid: 10815366].
25 Hirsch IB, Goldberg HI, Ellsworth A, et al. A multifaceted intervention in support of diabetes treatment guidelines: a controlled trial. Diabetes Res Clin Pract. Oct. 2002;58(1):27-36. PrvdrEd/workshops/materials/outreach, AuditFdbck, OrgChng/DxMx/team:clin information\Rmndr:Dz/HbA1c/BP. [pmid: 12161054].
26 Hoskins PL, Fowler PM, Constantino M, Forrest J, Yue DK, Turtle JR. Sharing the care of diabetic patients between hospital and general practitioners: does it work?. Diabet Med. Jan–Feb. 1993;10(1):81-86. OrgChng/other:Dz/HbA1c/BP/other, Adhere/HbA1c/HTN/other, Pat comp. [pmid: 8435994].
27 Hurwitz B, Goodman C, Yudkin J. Prompting the clinical care of non-insulin dependent (type II) diabetic patients in an inner city area: one model of community care. BMJ. Mar 6. 1993;306(6878):624-630. PtRmndr, FcltdRly:clin information\Rmndr:Dz/HbA1c/other. [pmid: 8461815]. [pmcid: 1676949].
28 Jaber LA, Halapy H, Fernet M, Tummalapalli S, Diwakaran H. Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother. Mar. 1996;30(3):238-243. PtEd, OrgChng/team:Dz/HbA1c/other. [pmid: 8833557].
29 Kiefe CI, Allison JJ, Williams OD, Person SD, Weaver MT, Weissman NW. Improving quality improvement using achievable benchmarks for physician feedback: a randomized controlled trial. JAMA. Jun 13. 2001;285(22):2871-2879. AuditFdbck:Adhere/HbA1c/footeye. [pmid: 11401608].
30 Kinmonth AL, Woodcock A, Griffin S, Spiegal N, Campbell MJ. Randomised controlled trial of patient centred care of diabetes in general practice: impact on current wellbeing and future disease risk. The Diabetes Care From Diagnosis Research Team. BMJ. Oct 31. 1998;317(7167):1202-1208. PtEd, PrvdrEd/workshops/materials:Dz/HbA1c/BP/other. [pmid: 9794859].
31 Kogan JR, Reynolds EE, Shea JA. Effectiveness of report cards based on chart audits of residents' adherence to practice guidelines on practice performance: a randomized controlled trial. Teach Learn Med. Winter. 2003;15(1):25-30. AuditFdbck:clin information\ID:Adhere/other. [pmid: 12632705].
32 Legorreta. Effect of a comprehensive nurse-managed diabetes program: an HMO prospective study. Am.J Managed Care. 1996/// 1996;2; 1024–30, 1996. JC CP:30:PtRmndr, PrvdrEd/workshops/materials, OrgChng/DxMx/other:clin information\Rmndr, CDSS:Dz/HbA1c/other
33 Levetan CS, Dawn KR, Robbins DC, Ratner RE. Impact of computer-generated personalized goals on HbA(1c). Diabetes Care. Jan. 2002;25(1):2-8. PtEd, SelfMx, PtRmndr, PrvRmndr, FcltdRly:Dz/HbA1c/BP/other. [pmid: 11772893].
34 Lim FS, Toh MP, Emmanuel SC, Chan SP, Lim G. A preliminary evaluation of a disease management programme for patients with diabetes mellitus and hypertension in a primary healthcare setting. Ann Acad Med Singapore. Jul. 2002;31(4):431-439. PtEd, PrvRmndr, OrgChng/DxMx:clin information\Rmndr, CDSS:Dz/HbA1c/BP/other(HbA1c)(BP). [pmid: 12161877].
35 Litzelman DK, Slemenda CW, Langefeld CD, et al. Reduction of lower extremity clinical abnormalities in patients with non-insulin-dependent diabetes mellitus. A randomized, controlled trial. Ann Intern Med. Jul 1. 1993;119(1):36-41. PtEd, PtRmndr, PrvdrEd/materials, PrvRmndr:clin information\ID:Dz/other, Pat comp. [pmid: 8498761].
36 Lobach DF, Hammond WE. Computerized decision support based on a clinical practice guideline improves compliance with care standards. Am J Med. Jan. 1997;102(1):89-98. PrvRmndr:clin information\ID, Rmndr, CDSS:Adhere/HbA1c/HTN/footeye/other. [pmid: 9209205].
37 Mazzuca SA, Moorman NH, Wheeler ML, et al. The diabetes education study: a controlled trial of the effects of diabetes patient education. Diabetes Care. Jan–Feb. 1986;9(1):1-10. PrvdrEd/workshops/materials, PrvRmndr, AuditFdbck:clin information\Rmndr:Dz/HbA1c/BP/other. [pmid: 3948638].
38 McDermott RA, Schmidt BA, Sinha A, Mills P. Improving diabetes care in the primary healthcare setting: a randomised cluster trial in remote Indigenous communities. Med J Aust. May 21. 2001;174(10):497-502. PtRmndr, PrvdrEd/workshops, PrvRmndr, AuditFdbck, OrgChng/medrcrd:Dz/other(HbA1c)(BP), Adhere/HbA1c/HTN/footeye/other. [pmid: 11419768].
39 Meigs JB, Cagliero E, Dubey A, et al. A controlled trial of web-based diabetes disease management: the MGH diabetes primary care improvement project. Diabetes Care. Mar. 2003;26(3):750-757. PrvdrEd/materials, PrvRmndr:clin information\Rmndr, CDSS:Dz/HbA1c/BP/other(HbA1c)(BP), Adhere/HbA1c/HTN/footeye/other. [pmid: 12610033].
40 O'Connor PJ, Rush WA, Peterson J, et al. Continuous quality improvement can improve glycemic control for HMO patients with diabetes. Arch Fam Med. Oct. 1996;5(9):502-506. PtEd, AuditFdbck, OrgChng/DxMx/Other:clin information\ID, Audit:Dz/HbA1c/other(HbA1c). [pmid: 8930220].
41 Oh JA, Kim HS, Yoon KH, Choi ES. A telephone-delivered intervention to improve glycemic control in type 2 diabetic patients. Yonsei Med J. Feb. 2003;44(1):1-8. PtEd, FcltdRly:Dz/HbA1c/other. [pmid: 12619168].
42 Olivarius NF, Beck-Nielsen H, Andreasen AH, Horder M, Pedersen PA. Randomised controlled trial of structured personal care of type 2 diabetes mellitus. BMJ. Oct 27. 2001;323(7319):970-975. PtEd, PrvdrEd/workshops, PrvRmndr, AuditFdbck:Dz/other(HbA1c)(BP). [pmid: 11679387]. [pmcid: 59690].
43 Ovhed I, Johansson E, Odeberg H, Rastam L. A comparison of two different team models for treatment of diabetes mellitus in primary care. Scand J Caring Sci. 2000;14(4):253-258. OrgChng/team:Adhere/HbA1c/HTN/footeye/other, Pat comp. [pmid: 12035216].
44 Palmer RH, Louis TA, Hsu LN, et al. A randomized controlled trial of quality assurance in sixteen ambulatory care practices. Med Care. Jun. 1985;23(6):751-770. AuditFdbck, OrgChng/other:Adhere/other. [pmid: 3892184].
45 Piette JD, Weinberger M, McPhee SJ, Mah CA, Kraemer FB, Crapo LM. Do automated calls with nurse follow-up improve self-care and glycemic control among vulnerable patients with diabetes?. Am J Med. Jan. 2000;108(1):20-27. PtEd, SelfMx, FcltdRly, OrgChng/team:Dz/HbA1c/other(HbA1c), Pat comp. [pmid: 11059437].
46 Piette JD, Weinberger M, Kraemer FB, McPhee SJ. Impact of automated calls with nurse follow-up on diabetes treatment outcomes in a Department of Veterans Affairs Health Care System: a randomized controlled trial. Diabetes Care. Feb. 2001;24(2):202-208. PtEd, SelfMx, PtRmndr, FcltdRly, OrgChng/team:Dz/HbA1c/other(HbA1c). [pmid: 11213866].
47 Pouwer F, Snoek FJ, van der Ploeg HM, Ader HJ, Heine RJ, IN. Monitoring of psychological well-being in outpatients with diabetes: effects on mood, HbA(1c), and the patient's evaluation of the quality of diabetes care: a randomized controlled trial. Diabetes Care. 2001/11// 2001;24(11):1929–1935:OrgChng/team:Dz/HbA1c
48 Reed RL, Revel AO, Carter A, Saadi HF, Dunn EV. A clinical trial of chronic care diabetic clinics in general practice in the United Arab Emirates: a preliminary analysis. Arch Physiol Biochem. Jul. 2001;109(3):272-280. PtEd, PrvdrEd/workshops/materials, FcltdRly, OrgChng/team/medrcrd:Dz/BP/other. [pmid: 11880932].
49 Renders CM, Valk GD, Franse LV, et al. Long-term effectiveness of a quality improvement program for patients with type 2 diabetes in general practice. Diabetes Care. 2001/08// 2001;24(8):1365–1370: PrvdrEd/workshops/materials, AuditFdbck:Dz/other(HbA1c)(BP), Adhere/HbA1c/HTN/other
50 Ronnemaa T, Hamalainen H, Toikka T, Liukkonen I. Evaluation of the impact of podiatrist care in the primary prevention of foot problems in diabetic subjects. Diabetes Care. Dec. 1997;20(12):1833-1837. PtEd, OrgChng/team:Dz/other, Pat comp. [pmid: 9405902].
51 Sadur CN, Moline N, Costa M, et al. Diabetes management in a health maintenance organization. Efficacy of care management using cluster visits. Diabetes Care. Dec. 1999;22(12):2011-2017. PtEd, PtRmndr, OrgChng/DxMx/team:clin information\ID:Dz/HbA1c, Pat comp. [pmid: 10587835].
52 Smith SA, Murphy ME, Huschka TR, et al. Impact of a diabetes electronic management system on the care of patients seen in a subspecialty diabetes clinic. Diabetes Care. Jun. 1998;21(6):972-976. OrgChng/medrcrd:clin information\Other:Dz/HbA1c/BP, Adhere/HbA1c/footeye/edu/other. [pmid: 9614616].
53 Stroebel RJ, Scheitel SM, Fitz JS, et al. A randomized trial of three diabetes registry implementation strategies in a community internal medicine practice. Jt Comm J Qual Improv. Aug. 2002;28(8):441-450. OrgChng/other:clin information\ID:Dz/HbA1c/other(HbA1c)(BP), Adhere/HbA1c/other. [pmid: 12174408].
54 Thompson DM, Kozak SE, Sheps S. Insulin adjustment by a diabetes nurse educator improves glucose control in insulin-requiring diabetic patients: a randomized trial. CMAJ. Oct 19. 1999;161(8):959-962. PtEd, FcltdRly, OrgChng/team:Dz/HbA1c. [pmid: 10551191]. [pmcid: 1230704].
55 Vaughan NJ, Potts A. Implementation and evaluation of a decision support system for type II diabetes. Comput Methods Programs Biomed. Aug. 1996;50(3):247-251. OrgChng/team:Dz/other(HbA1c), Adhere/HbA1c. [pmid: 8894384].
56 Wagner EH, Grothaus LC, Sandhu N, et al. Chronic care clinics for diabetes in primary care: a system-wide randomized trial. Diabetes Care. Apr. 2001;24(4):695-700. PtEd, SelfMx, OrgChng/team:clin information\ID:Dz/HbA1c/other, Adhere/footeye/other. [pmid: 11315833].
57 Walker EA, Engel SS, Zybert PA, IN. Dissemination of diabetes care guidelines: lessons learned from community health centers. Diabetes Educator. 2001/01// 2001;27(1):101–110:PrvdrEd/workshops/materials/outreach:Adhere/HbA1c/footeye/other
58 Ward A, Kamien M, Mansfield F, Fatovich B. Educational feedback in the management of type 2 diabetes in general practice. Education for General Practice. 1996/// 1996;7:142–150:PrvdrEd/materials/outreach, AuditFdbck:Adhere/HbA1c/HTN/footeye/edu/other
59 Weinberger M, Kirkman MS, Samsa GP, et al. A nurse-coordinated intervention for primary care patients with non-insulin-dependent diabetes mellitus: impact on glycemic control and health-related quality of life. J Gen Intern Med. Feb. 1995;10(2):59-66. PtEd, SelfMx, PtRmndr, FcltdRly, OrgChng/DxMx:clin information\ID:Dz/HbA1c/other. [pmid: 7730940].