# Articles excluded solely on the basis that intervention focused only on patient education or promotion of self-management

## References

1 Anderson RM, Funnell MM, Butler PM, Arnold MS, Fitzgerald JT, Feste CC. Patient empowerment. Results of a randomized controlled trial. Diabetes Care. 1995;18:943-949. [pmid: 7555554].
2 Barth R, Campbell LV, Allen S, Jupp JJ, Chisholm DJ. Intensive education improves knowledge, compliance, and foot problems in type 2 diabetes. Diabet Med. 1991;8:111-117. [pmid: 1827394].
3 Boehm S, Schlenk EA, Raleigh E, Ronis D. Behavioral analysis and behavioral strategies to improve self-management of type II diabetes. Clin Nurs Res. 1993;2:327-344. [pmid: 8401245].
4 Brown SA, Garcia AA, Kouzekanani K, Hanis CL. Culturally competent diabetes self-management education for Mexican Americans: the Starr County border health initiative. Diabetes Care. 2002;25:259-268. [pmid: 11815493]. [pmcid: 2134805].
5 Cooper HC, Booth K, Gill G, IN. Patients' perspectives on diabetes health care education. Health Education Research. 2003;18:191–206.
6 Corbett CF, IN. A randomized pilot study of improving foot care in home health patients with iabetes. Diabetes Educator. 2003;29:273–282.
7 Domenech MI, Assad D, Mazzei ME, Kronsbein P, Gagliardino JJ. Evaluation of the effectiveness of an ambulatory teaching/treatment programme for non-insulin dependent (type 2) diabetic patients. Acta Diabetol. 1995;32:143-147. [pmid: 8590781].
8 Estey AL, Tan MH, Mann K. Follow-up intervention: its effect on compliance behavior to a diabetes regimen. Diabetes Educ. 1990;16:291-295. [pmid: 2357919].
9 Gilliland SS, Azen SP, Perez GE, Carter JS. Strong in body and spirit: lifestyle intervention for Native American adults with diabetes in New Mexico. Diabetes Care. 2002;25:78-83. [pmid: 11772905].
10 Glasgow RE, Toobert DJ, Hampson SE, Strycker LA. Implementation, generalization and long-term results of the “choosing well” diabetes self-management intervention. Patient Educ Couns. 2002;48:115-122. [pmid: 12401414].
11 Goldhaber-Fiebert JD, Goldhaber-Fiebert SN, Tristan ML, Nathan DM. Randomized controlled community-based nutrition and exercise intervention improves glycemia and cardiovascular risk factors in type 2 diabetic patients in rural Costa Rica. Diabetes Care. 2003;26:24-29. [pmid: 12502654].
12 Greenfield S, Kaplan SH, Ware JE Jr, Yano EM, Frank HJ. Patients' participation in medical care: effects on blood sugar control and quality of life in diabetes. J Gen Intern Med. 1988;3:448-457. [pmid: 3049968].
13 Halbert RJ, Leung KM, Nichol JM, Legorreta AP. Effect of multiple patient reminders in improving diabetic retinopathy screening. A randomized trial. Diabetes Care. 1999;22:752-755. [pmid: 10332676].
14 Hendricks LE, Hendricks RT. The effect of diabetes self-management education with frequent follow-up on the health outcomes of African American men. Diabetes Educ. 2000;26:995-1002. [pmid: 11912812].
15 Hiss RG, Gillard ML, Armbruster BA, McClure LA. Comprehensive evaluation of community-based diabetic patients: effect of feedback to patients and their physicians: a randomized controlled trial. Diabetes Care. 2001;24:690-694. [pmid: 11315832].
16 Hopper SV, Miller JP, Birge C, Swift J. A randomized study of the impact of home health aides on diabetic control and utilization patterns. Am J Public Health. 1984;74:600-602. [pmid: 6721016]. [pmcid: 1651641].
17 Pieber Evaluation of a structured teaching and treatment programme for type2 diabetes in general ractice in a rural area of Austria Diabetes Medicine 1995 112:349–354.
18 Krier BP, Parker RD, Grayson D, Byrd G. Effect of diabetes education on glucose control. J La State Med Soc. 1999;151:86-92. [pmid: 11280842].
19 Lafata JE, Baker AM, Divine GW, McCarthy BD, Xi H. The use of computerized birthday greeting reminders in the management of diabetes. J Gen Intern Med. 2002;17:521-530. [pmid: 12133142]. [pmcid: 1495071].
20 Lo R, Lo B, Wells E, Chard M, Hathaway J. The development and evaluation of a computer-aided diabetes education program. Aust J Adv Nurs. 1996;13:19-27. [pmid: 8900703].
21 Lustman PJ, Griffith LS, Freedland KE, Kissel SS, Clouse RE. Cognitive behavior therapy for depression in type 2 diabetes mellitus. A randomized, controlled trial. Ann Intern Med. 1998;129:613-621. [pmid: 9786808].
22 Malone JM, Snyder M, Anderson G, Bernhard VM, Holloway GA Jr, Bunt TJ. Prevention of amputation by diabetic education. American Journal of Surgery. 1989;158:520-523. [pmid: 2589581].
23 McCabe CJ, Stevenson RC, Dolan AM. Evaluation of a diabetic foot screening and protection rogramme. Diabet Med. 1998;15:80-84. [pmid: 9472868].
24 Mulrow C, Bailey S, Sonksen PH, Slavin B. Evaluation of an Audiovisual Diabetes Education rogram: negative results of a randomized trial of patients with non-insulin-dependent diabetes mellitus. J Gen Intern Med. 1987;2:215-219. [pmid: 2441013].
25 Noel PH, Larme AC, Meyer J, Marsh G, Correa A, Pugh JA. Patient choice in diabetes education curriculum. Nutritional versus standard content for type 2 diabetes. Diabetes Care. 1998;21:896-901. [pmid: 9614604].
26 Pill R, Stott NC, Rollnick SR, Rees M. A randomized controlled trial of an intervention designed to mprove the care given in general practice to Type II diabetic patients: patient outcomes and professional ability to change behaviour. Fam Pract. 1998;15:229-235. [pmid: 9694180].
27 Rabkin SW, Boyko E, Wilson A, Streja DA. A randomized clinical trial comparing behavior modification and individual counseling in the nutritional therapy of non-insulin-dependent diabetes mellitus: comparison of the effect on blood sugar, body weight, and serum lipids. Diabetes Care. 1983;6:50-56. [pmid: 6341015].
28 Ridgeway NA, Harvill DR, Harvill LM, Falin TM, Forester GM, Gose OD. Improved control of type 2 diabetes mellitus: a practical education/behavior modification program in a primary care clinic. South Med J. 1999;92:667-672. [pmid: 10414474].
29 Rutten G, van Eijk J, de Nobel E, Beek M, van der Velden H. Feasibility and effects of a diabetes type II protocol with blood glucose self-monitoring in general practice. Fam Pract. 1990;7:273-278. [pmid: 2289639].
30 Samaras K, Ashwell S, Mackintosh AM, Fleury AC, Campbell LV, Chisholm DJ. Will older sedentary people with non-insulin-dependent diabetes mellitus start exercising? A health promotion model. Diabetes Res Clin Pract. 1997;37:121-128. [pmid: 9279482].
31 Schwedes U, Siebolds M, Mertes G. Meal-related structured self-monitoring of blood glucose: effect on diabetes control in non-insulin-treated type 2 diabetic patients. Diabetes Care. 2002;25:1928-1932. [pmid: 12401734].
32 Shandro MT, Pick ME, Gruninger A, Ryan EA, IN. Diabetes care: interventions in the community. Diabetes Care. 2002;25:941–942.
33 Skaer TL, Sclar DA, Markowski DJ, Won JK. Effect of value-added utilities on prescription refill compliance and Medicaid health care expenditures—a study of patients with non-insulin-dependent diabetes mellitus. J Clin Pharm Ther. 1993;18:295-299. [pmid: 8227238].
34 Smith DM, Weinberger M, Katz BP. A controlled trial to increase office visits and reduce hospitalizations of diabetic patients. J Gen Intern Med. 1987;2:232-238. [pmid: 3612344].
35 Smith DE, Heckemeyer CM, Kratt PP, Mason DA. Motivational interviewing to improve adherence to a behavioral weight-control program for older obese women with NIDDM. A pilot study. Diabetes Care. 1997;20:52-54. [pmid: 9028693].
36 Surwit RS, van Tilburg MA, Zucker N, et al. Stress management improves long-term glycemic control in type 2 diabetes. Diabetes Care. 2002;25:30-34. [pmid: 11772897].
37 Trento M, Passera P, Bajardi M, et al. Lifestyle intervention by group care prevents deterioration of Type II diabetes: a 4-year randomized controlled clinical trial. Diabetologia. 2002;45:1231-1239. [pmid: 12242455].
38 Tsang MW, Mok M, Kam G, et al. Improvement in diabetes control with a monitoring system based on a hand-held, touch-screen electronic diary. J Telemed Telecare. 2001;7:47-50. [pmid: 11265938].
39 Tu KS, McDaniel G, Gay JT. Diabetes self-care knowledge, behaviors, and metabolic control of older adults—the effect of a posteducational follow-up program. Diabetes Educator. 1993;19:25-30. [pmid: 8458295].
40 Werdier D, Jesdinsky HJ, Helmich P. A randomized, controlled study on the effect of diabetes counseling in the offices of 12 general practitioners. Rev Epidemiol Sante Publique. 1984;32:225-229. [pmid: 6522737].
41 White N, Carnahan J, Nugent CA, Iwaoka T, Dodson MA. Management of obese patients with diabetes mellitus: comparison of advice education with group management. Diabetes Care. 1986;9:490-496. [pmid: 3769719].
42 Wing RR, Epstein LH, Nowalk MP, Scott N, Koeske R, Hagg S. Does self-monitoring of blood glucose levels improve dietary compliance for obese patients with type II diabetes?. Am J Med. 1986;81:830-836. [pmid: 3535493].
43 Wise PH, Dowlatshahi DC, Farrant S, Fromson S, Meadows KA. Effect of computer-based learning on diabetes knowledge and control. Diabetes Care. 1986;9:504-508. [pmid: 3533475].
44 de Weerdt I, Visser AP, Kok GJ, de Weerdt O, van der Veen EA. Randomized controlled multicentre evaluation of an education programme for insulin-treated diabetic patients: effects on metabolic control, quality of life, and costs of therapy. Diabet Med. 1991;8:338-345. [pmid: 1830257].
45 D'Eramo-Melkus GA, Wylie-Rosett J, Hagan JA. Metabolic impact of education in NIDDM. Diabetes Care. 1992;15:864-869. [pmid: 1516506].
46 Raz I, Soskolne V, Stein P. Influence of small-group education sessions on glucose homeostasis in NIDDM. Diabetes Care. 1988;11:67-71. [pmid: 3338379].
47 Agurs C, et al. A randomized controlled trial of weight reduction and exercise for diabetes management in African-American subjects. Diabetes Care. 1997;20:1503. [pmid: 9314625].
48 Bloomgarden, et al. Randomized, controlled trial of diabetic patient education: improved knowledge ithout improved metabolic status. Diabetes Care. 1987;10:263. [pmid: 3297575].
49 Campbell, et al. The relative effectiveness of educational and behavioral instruction programs for patients with NIDDM: a randomized trial. Diabetes Educ. 1996;22:379. [pmid: 8846745].
50 Corkery, et al. Effect of a bicultural community health worker on completion of diabetes education in a Hispanic population. Diabetes Care. 1997;20:254. [pmid: 9051367].
51 Falkenberg, et al. Problem oriented participatory education in the guidance of adults with non-insulin-treated type-II diabetes mellitus. Scand J Prim Health Care. 1986;4:157. [pmid: 3775139].
52 Gilden, et al. Diabetes support groups improve health care of older diabetic patients. J Am Geriatr Soc. 1992;40:147. [pmid: 1740599].
53 Hawthorne K, Tomlinson S. One-to-one teaching with pictures - flashcard health education for British Asians with diabetes. Br J Gen Pract. 1997;47:301. [pmid: 9219407]. [pmcid: 1313005].
54 Heller, et al. Group education for obese patients with type 2 diabetes: greater success at less cost. Diabet Med. 1988;5:552. [pmid: 2974778].
55 Kronsbein, et al. Evaluation of a structured treatment and teaching programme on non-insulin dependent diabetes. Lancet. 1988;2:1407. [pmid: 2904532].
56 Pratt, et al. Peer support and nutrition education for older adults with diabetes. J Nutr Elder. 1987;6:31. [pmid: 3656067].
57 Izquierdo PEKSMJKRP-S, Weinstock RS. A comparison of diabetes education administered through telemedicine versus in person. Diabetes Care. 2003;26:1002-1007. [pmid: 12663564].
58 Scott, et al. TThe effectiveness of diabetes education for non-insulin-dependent diabetic persons. Diabetes Educ. 1984;10:36. [pmid: 6562009].
59 Uusitupa, et al. The maintenance of improved metabolic control after intensified diet therapy in recent type 2 diabetes. Diabetes Res Clinic Pract. 1993;19:227.
60 Trento M, et al. Therapeutic group education in the follow-up of patients with non-insulin treated, non-insulin dependent diabetes mellitus. Diabetes Metab Clin Exp. 1998;11:212-216.
61 Daniel M, Green LW, Marion SA, et al. Effectiveness of community-directed diabetes prevention and control in a rural Aboriginal population in British Columbia, Canada. Soc Sci Med. 1999;48:815-832. [pmid: 10190643].
62 Hanefeld M, Fischer S, Schmechel H, et al. Diabetes Intervention Study. Multi-intervention trial in newly diagnosed NIDDM. Diabetes Care. 1991;14:308-317. [pmid: 2060433].
63 Karlander SG, Kindstedt K. Effects of a formalized diabetes education. Acta Med Scand. 1983;213:41-43. [pmid: 6829317].
64 Perry TL, Mann JI, Lewis-Barned NJ, Duncan AW, Waldron MA, Thompson C. Lifestyle intervention in people with insulin-dependent diabetes mellitus (IDDM). Eur J Clin Nutr. 1997;51:757-763. [pmid: 9368810].
65 Raji A, Gomes H, Beard JO, MacDonald P, Conlin PR. A randomized trial comparing intensive and passive education in patients with diabetes mellitus. Arch Intern Med. 2002;162:1301-1304. [pmid: 12038949].
66 Trento M, Passera P, Tomalino M, et al. Group visits improve metabolic control in type 2 diabetes: a 2-year follow-up. Diabetes Care. 2001;24:995-1000. [pmid: 11375359].
67 Wilson W, Pratt C. The impact of diabetes education and peer support upon weight and glycemic control of elderly persons with noninsulin dependent diabetes mellitus (NIDDM). Am J Public Health. 1987;77:634-635. [pmid: 3565666]. [pmcid: 1647053].
68 Glasgow RE, Toobert DJ, Hampson SE, Brown JE, Lewinsohn PM, Donnelly J. Improving self-care among older patients with type II diabetes: the “Sixty Something...” Study. Patient Educ Couns. 1992;19:61-74. [pmid: 1298950].