# Abstraction forms for screening and full-text review

To see the Abstraction forms for screening and full-text review, please select the link below. This link will take you to a PDF version of the forms.

Abstraction forms for screening and full-text review