# MEDLINE search for diabetes quality improvement articles

Search | Search String | Citations *
#1 targets QI strategies that tend to be multi-factorial using relevant MeSH terms and title words | Disease Management [mh] OR Patient Care Planning [mh] OR Patient-Centered Care [mh] OR Primary Health Care [mh] OR Progressive Patient Care [mh] OR Critical Pathways [mh] OR Delivery of Health Care, Integrated [mh] OR Health Services Accessibility [mh] OR Managed Care Programs [mh] OR Product Line Management [mh] OR Patient Care Team [mh] OR Patient-Centered Care [mh] OR Behavior Control [mh] OR Counseling [mh] OR Health Promotion [mh] OR Patient Compliance [mh] OR After-Hours Care [mh] OR ((coordination [ti] OR coordinated [ti] OR Multifactorial [ti] OR Multi-factorial [ti] OR Multicomponent [ti] OR Multi-component [ti] OR multidisciplinary [ti] OR multi-disciplinary [ti] OR interdisciplinary [ti] OR inter-disciplinary [ti] OR integrated [ti] OR community-based [ti] OR organized [ti]) AND (care [ti] OR approach [ti] OR intervention [ti] OR strategy [ti] OR strategies [ti] OR management [ti] OR managing [ti] OR center* [ti] OR clinic*[ti])) OR Organization and Administration [mh] | 682,850
#2 targets TQM and CQI | Total Quality Management [mh] OR Quality control [mh] OR TQM [ti] OR CQI [ti] OR (quality [ti] AND (continuous [ti] OR total [ti]) AND (management [ti] OR improvement [ti])) | 28,079
#3 targets provider education | Education, Continuing [mh] OR (Education [ti] AND Continuing [ti] AND (medical [ti] OR professional* [ti] OR nursing [ti] OR physician* [ti] OR nurse* [ti])) OR (outreach [ti] AND (visit*[ti] OR educational [ti]) OR (academic [ti] AND detailing [ti])) | 35,275
#4 targets diffusion of innovation | Diffusion of Innovation [mh] OR (Diffusion [ti] AND (Innovation [ti] OR technology [ti])) | 4,887
#5 targets audit & feedback, reminder systems, and financial incentives | Medical audit [mh] OR ((Audit [ti] OR feedback [ti] OR compliance [ti] OR adherence [ti] OR training [ti]) AND (improvement* [ti] OR improving [ti] OR improves [ti] OR improve [ti] OR guideline* [ti] OR practice* [ti] OR medical [ti] OR provider* [ti] OR physician* [ti] OR nurse* [ti] OR clinician* [ti] OR practice guidelines [mh] OR academic [ti] OR visit* [ti])) OR Reminder Systems [mh] OR Reminder* [ti] OR ((financial [ti] OR economic [ti] OR physician* [ti] OR patient*) AND incentive* [ti]) OR Reimbursement Mechanisms [mh] | 36,788
#6 targets informatics and telemedicine | Medical Informatics [mh] OR computer [ti] OR (decision [ti] AND support [ti]) OR Telemedicine[mh] OR Telemedicine [ti] OR telecommunication* [ti] OR Internet [mh] OR web [ti] OR modem [ti] OR telephone* [ti] OR telephone [mh] | 306,619
#7 combines #1–7 for overall set of articles relating to QI | #1 OR #2 OR #3 OR #4 OR #5 OR #6 | 988,084
#8 combines overall QI search key terms for articles involving diabetes | #7 AND (Diabetes Mellitus [mh] OR diabetes [ti] OR diabetic [ti] OR glycemic [ti] OR glycaemic [ti] OR sugar* [ti]) | 9,956
#9 identifies subset of #9 likely to involve original research or systematic reviews | #8 AND (systematic review search stringˆ OR original research string ^†^) | 3,992
#10 | #9 Limit to English | 3,575
#11 | #10 Limit to publication since 1980 | 3,460
#12 | #11 BUTNOT (editorial [pt] OR comment [pt] OR letter [pt]) | 3,348
#13 additional yield of journal search | (#8 AND Journal Search String ^§^) BUTNOT (#9 OR editorial [pt] OR comment [pt] OR letter [pt]) [Limited to English, 1980] | 294
#14 additional yield of author search | (#8 AND author search**) BUTNOT (#13 OR editorial [pt] OR comment [pt] OR letter [pt]) [Limited to English, 1980] | 29
Total | #12 or #13 or #14 | 3,601 references total

* Numbers of citations reflect search results from July 8, 2003

ˆ ((meta-analysis [pt] OR meta-analysis [tw] OR metanalysis [tw]) OR ((review [pt] OR guideline [pt] OR consensus [ti] OR guideline* [ti] OR literature [ti] OR overview [ti] OR review [ti] OR Decision Support Techniques [mh]) AND ((Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw])) OR (handsearch* [tw] OR search* [tw] OR searching [tw]) AND (hand [tw] OR manual [tw] OR electronic [tw] OR bibliographi* [tw] OR database* OR (Cochrane [tw] OR Medline [tw] OR CINAHL [tw] OR (National [tw] AND Library [tw]))))) OR ((synthesis [ti] OR overview [ti] OR review [ti] OR survey [ti]) AND (systematic [ti] OR critical [ti] OR methodologic [ti] OR quantitative [ti] OR qualitative [ti] OR literature [ti] OR evidence [ti] OR evidence-based [ti]))) BUTNOT (case report [mh] OR case* [ti] OR report [ti] OR editorial [pt] OR comment [pt] OR letter [pt]) → 38,850 MEDLINE records

† Randomised [ti] OR Randomized [ti] OR Controlled [ti] OR intervention [ti] OR evaluation [ti] OR impact [ti] OR effectiveness [ti] OR Evaluation [ti] OR Studies [ti] OR study [ti] Comparative [ti] OR Feasibility [ti] OR Program [ti] OR Design [ti] OR Clinical Trial [pt] OR Randomized Controlled Trial [pt] OR Epidemiologic Studies [mh] OR Evaluation Studies [mh] OR Comparative Study [mh] OR Feasibility Studies [mh] OR Intervention Studies [mh] OR Program Evaluation [mh] OR Epidemiologic Research Design [mh] → 2,550,756 MEDLINE records

§ N Engl J Med [ta] OR JAMA [ta] OR Ann Intern Med [ta] OR Am J Med [ta] OR Arch Intern Med [ta] OR J Gen Intern Med [ta] OR BMJ [ta] OR Lancet [ta] OR CMAJ [ta] OR Clin Invest Med [ta] OR Arch Fam Med [ta] OR J Fam Pract [ta] OR Fam Pract [ta] OR Ann Med [ta] OR Br J Gen Pract [ta] OR J Intern Med [ta] OR Med J Aust [ta] OR South Med J [ta] OR West J Med [ta] OR Aust N Z J Med [ta] OR Med Care [ta] OR Health Serv Res [ta] OR Inquiry [ta] OR Milbank Q [ta] OR Health Aff (Millwood) [ta] OR Health Care Financ Rev [ta] OR Med Care Res Rev [ta] OR eff clin pract [ta] OR eval health prof [ta] OR Jt Comm J Qual Improv [ta] OR Qual Saf Health Care [ta] OR Int J Qual Health Care [mh] OR Qual Health Care [ta] OR Qual Health Res [ta] OR Rep Med Guidel Outcomes Res [ta] OR Am J Manag Care [ta] OR Am J Med Qual [ta] OR J Contin Educ Health Prof [ta] OR Prev Med [ta] OR Am J Prev Med [ta] OR Patient Educ Couns [ta] OR Ann Behav Med [ta] OR Diabetes Educ [ta] OR Endocrinology [ta] OR J Clin Endocrinol Metab [ta] OR Diabet Med [ta] OR Diabetes Care [ta] OR Diabetes Res Clin Pract [ta] OR Exp Clin Endocrinol Diabetes [ta] OR J Pediatr Endocrinol Metab [ta]

** The author search could not be exhaustive, but, after completion of the initial search, we identified authors who appeared in multiple trials or prominent review articles and searched for publications listing any of them as authors (list available on request)