# Comparison of recommended goals for clinical practice vs. targets for performance measurement

| Goal for clinical practice | Target for performance measurement | Comment
Adequacy of Glycemic Control | “good control”: HbA_1c_ ≤ 7.0% ADA ^1^ | Proportion of patients with “poor control”:; - HbA_1c_ ≥ 9% NDQIA ^2^; - HbA_1c_ ≥ 9.5%) ^3^ | Many factors effect the appropriateness of HbA_1c_ < 7% as a fixed goal for a clinic or health care system to achieve (e.g., frequency of hypoglycemia, comorbid conditions, patient preferences), hence the focus on percentage of patients with “poor control” (≥ 9%) for purposes of performance measurement
Blood pressure control | < 130/80 mmHg | ≤ 140/90 mmHg | Similarly, system-wide reports of BP control focus on percentage of patients with poor control (≥ 140/90 mmHg)
Lipid control | LDL-C ≤ 100 mg/dl (2.6 mmol/l) | LDL-C ≤ 130 mg/dl | Elevated LDL-cholesterol is most strongly correlated with increased risk of cardiovascular disease. Again, optimal goal of 100 mg/dl may not be attainable for numerous reasons.
| Triglycerides ≤ 150 mg/dl (1.7 mmol/l)
| HDL ≤ 40 mg/dl (1.1 mmol/l)
Frequency of assessing HbA_1c_ | ≥ 2 times/year for patients meeting treatment goals; ^1^ | ≥ 1 HbA_1c_ test/year (NDQIA,2 HEDIS^®^ ^3^ ) | Yearly measurements of HbA_1c_ are correlated with actual lower HbA_1c_ levels.
| ≥ 4 times/year patients not meeting treatment goals ^1^
Frequency of assessing lipids | > 1 complete lipid panel/year ^1^ | ≥ 1 LDL-C measurement/year (NDQIA, ^2^ HEDIS ^3^ )
Urine protein screening | ≥1 test for urine microalbumin/year ^1^ | ≥ 1 test for urine microalbumin/year(NDQIA, ^2^ HEDIS ^3^ ) | Receives only an “E” recommendation from ADA (“Expert consensus or clinical practice”) for type 2 diabetic patients.
Eye examination | ≥1 dilated retinal examination/year ^1^ | ≥ 1 dilated retinal examination/year (or every other year if low risk) | “Low risk”: non-insulin-requiring, HbA_1c_ < 8%, no prior evidence of retinopathy
Foot examination | ≥ 1 complete foot exam/year (including sensory exam with microfilament) ^1^ | ≥ 1 foot examination of any kind
Smoking cessation | Advise all smokers to quit; smoking cessation as part of routine diabetic care ^1^ | Percentage of patients whose smoking
| | status was ascertained and documented annually
Patient education | No formal recommendation | No formal recommendation

ADA - American Diabetes Association; NDQIA - National Diabetes Quality Improvement Alliance; HEDIS - Health Plan Employer Data and Information Set. The HEDIS measure is actually a composite measures for “comprehensive diabetes care” consisting of the specific measurements show in the table.

## References

1 American Diabetes Association. Standards of medical care for patients with diabetes mellitus. Diabetes Care. 2003;26 Suppl 1:S33–50.
2 National Diabetes Aliance. National Diabetes Quality Improvement Alliance Performance Measurement Set for Adult Diabetes. Available at: http://www.nationaldiabetesalliance.org/Final_03_Measures.pdf. Accessed November 16, 2003.
3 National Committee for Quality Assurance (NCQA). HEDIS Effectiveness of Care Measure-by-Measure Reports: Comprehensive Diabetes Care. Available at: http://www.ncqa.org/sohc2002/SOHC_2002_CDIAB.html. Accessed November 17, 2003.