# Appendixes

Appendix A Comparison of recommended goals for clinical practice vs. targets for performance measurement

Appendix B MEDLINE search for diabetes quality improvement articles

Appendix C Abstraction forms for screening and full-text review

Appendix D Articles excluded solely on the basis that intervention focused only on patient education or promotion of self-management

Appendix E Summary of results for each included study

Appendix F Calculation of effective sample sizes for trials with clustering

Appendix G Articles excluded at the level of full-text review

Appendix H Additional tables for diabetes results and analysis