# References

1 Priority Areas for National Action: Transforming Health Care Quality. Washington, DC: National Academy Press; 2003.
2 National Healthcare Quality Report: Update. Rockville, MD: Agency for Healthcare Research and Quality; 2002 June. Report No.: 02-P028.
3 National Healthcare Disparities Report. Background. 2002 November; Available from: http://www.ahrq.gov/qual/nhdr02/nhdrprelim.htm. Accessed 2003.
4 Institute of Medicine. Crossing the Quality Chasm: A New Health System for the 21st Century. Washington, DC: National Academy Press; 2001.
5 Mallon B, Mallon W. Ernest Amory Codman: The End Result of a Life in Medicine. Philadelphia: WB Saunders; 2000.
6 Dickersin K, Rennie D. Registering clinical trials. JAMA. 2003;290(4):516-23. [pmid: 12876095].
7 Chassin MR, Galvin RW. The urgent need to improve health care quality. Institute of Medicine National Roundtable on Health Care Quality. JAMA. 1998;280(11):1000-5. [pmid: 9749483].
8 Kohn L, Corrigan J, Donaldson M, Committee on Quality of Health Care in America IoM, editors. To Err Is Human: Building a Safer Health System. Washington, D.C.: National Academy Press; 1999.
9 Wennberg J, Gittelsohn A. Variations in medical care among small areas. Sci Am. 1982;246(4):120-34. [pmid: 7079718].
10 Wennberg J, Gittelsohn A. Small area variations in health care delivery. Science. 1973;182(117):1102-8. [pmid: 4750608].
11 Merrick NJ, Brook RH, Fink A, Solomon DH. Use of carotid endarterectomy in five California Veterans Administration medical centers. JAMA. 1986;256(18):2531-5. [pmid: 3773153].
12 Brook RH, Lohr KN. Efficacy, effectiveness, variations, and quality. Boundary-crossing research. Med Care. 1985;23(5):710-22. [pmid: 3892183].
13 Roper WL, Winkenwerder W, Hackbarth GM, Krakauer H. Effectiveness in health care. An initiative to evaluate and improve medical practice. N Engl J Med. 1988;319(18):1197-202. [pmid: 3173456].
14 Krumholz HM, Radford MJ, Wang Y, Chen J, Heiat A, Marciniak TA. National use and effectiveness of beta-blockers for the treatment of elderly patients after acute myocardial infarction: National Cooperative Cardiovascular Project. JAMA. 1998;280(7):623-9. [pmid: 9718054].
15 Wennberg DE, Lucas FL, Birkmeyer JD, Bredenberg CE, Fisher ES. Variation in carotid endarterectomy mortality in the Medicare population: trial hospitals, volume, and patient characteristics. JAMA. 1998;279(16):1278-81. [pmid: 9565008].
16 Katzan IL, Furlan AJ, Lloyd LE, Frank JI, Harper DL, Hinchey JA, et al. Use of tissue-type plasminogen activator for acute ischemic stroke: the Cleveland area experience. JAMA. 2000;283(9):1151-8. [pmid: 10703777].
17 Flum DR, Morris A, Koepsell T, Dellinger EP. Has misdiagnosis of appendicitis decreased over time? A population-based analysis. JAMA. 2001;286(14):1748-53. [pmid: 11594900].
18 Decline in deaths from heart disease and stroke—United States, 1900-1999.MMWR Morb Mortal Wkly Rep 1999;48(30):649–56.
19 Schuster MA, McGlynn EA, Brook RH. How good is the quality of health care in the United States? Milbank Q 1998;76(4):517–63, 509.
20 Jencks SF, Cuerdon T, Burwen DR, Fleming B, Houck PM, Kussmaul AE, et al. Quality of medical care delivered to Medicare beneficiaries: A profile at state and national levels. JAMA. 2000;284(13):1670-6. [pmid: 11015797].
21 Wenger N, Solomon D, Roth C, MacLean C, Saliba D, Kamberg C, et al. The quality of medical care provided to vulnerable community-dwelling older patients. Ann Intern Med. 2003;139(9):740-747. [pmid: 14597458].
22 McGlynn EA, Asch SM, Adams J, Keesey J, Hicks J, DeCristofaro A, et al. The quality of health care delivered to adults in the United States. N Engl J Med. 2003;348(26):2635-45. [pmid: 12826639].
23 Leape LL. Translating medical science into medical practice. Do we need a national medical standards board?. JAMA. 1995;273(19):1534-7. [pmid: 7739082].
24 Davis DA, Taylor-Vaisey A. Translating guidelines into practice. A systematic review of theoretic concepts, practical experience and research evidence in the adoption of clinical practice guidelines. CMAJ. 1997;157(4):408-16. [pmid: 9275952]. [pmcid: 1227916].
25 Bero LA, Grilli R, Grimshaw JM, Harvey E, Oxman AD, Thomson MA. Closing the gap between research and practice: an overview of systematic reviews of interventions to promote the implementation of research findings. The Cochrane Effective Practice and Organization of Care Review Group. BMJ. 1998;317(7156):465-8. [pmid: 9703533]. [pmcid: 1113716].
26 Grol R, Grimshaw J. Evidence-based implementation of evidence-based medicine. Jt Comm J Qual Improv. 1999;25(10):503-13. [pmid: 10522231].
27 Ayanian JZ, Hauptman PJ, Guadagnoli E, Antman EM, Pashos CL, McNeil BJ. Knowledge and practices of generalist and specialist physicians regarding drug therapy for acute myocardial infarction. N Engl J Med. 1994;331(17):1136-42. [pmid: 7935639].
28 Donohoe MT. Comparing generalist and specialty care: discrepancies, deficiencies, and excesses. Arch Intern Med. 1998;158(15):1596-608. [pmid: 9701093].
29 Breuer T, Goodman KJ, Malaty HM, Sudhop T, Graham DY. How do clinicians practicing in the U.S. manage Helicobacter pylori- related gastrointestinal diseases? A comparison of primary care and specialist physicians. Am J Gastroenterol. 1998;93(4):553-61. [pmid: 9576447].
30 Chin MH, Friedmann PD, Cassel CK, Lang RM. Differences in generalist and specialist physicians' knowledge and use of angiotensin-converting enzyme inhibitors for congestive heart failure. J Gen Intern Med. 1997;12(9):523-30. [pmid: 9294785]. [pmcid: 1497156].
31 van den Berghe G, Wouters P, Weekers F, Verwaest C, Bruyninckx F, Schetz M, et al. Intensive insulin therapy in the critically ill patients. N Engl J Med. 2001;345(19):1359-67. [pmid: 11794168].
32 Greco PJ, Eisenberg JM. Changing physicians' practices. N Engl J Med. 1993;329(17):1271-3. [pmid: 8413397].
33 20 Tips to Help Prevent Medical Errors. Patient Fact Sheet [online]. AHRQ Publication No. 00-P038. 2000 February [cited 2003 November 30]; Available from: http://www.ahrq.gov/consumer/20tips.htm.
34 Mehrotra A, Bodenheimer T, Dudley RA. Employers' efforts to measure and improve hospital quality: determinants of success. Health Aff (Millwood). 2003;22(2):60-71. [pmid: 12674408].
35 Krumholz HM, Rathore SS, Chen J, Wang Y, Radford MJ. Evaluation of a consumer-oriented internet health care report card: the risk of quality ratings based on mortality data. JAMA. 2002;287(10):1277-87. [pmid: 11886319].
36 Gandhi TK, Francis EC, Puopolo AL, Burstin HR, Haas JS, Brennan TA. Inconsistent report cards: assessing the comparability of various measures of the quality of ambulatory care. Med Care. 2002;40(2):155-65. [pmid: 11802088].
37 Poses RM, McClish DK, Smith WR, Huber EC, Clemo FL, Schmitt BP, et al. Results of report cards for patients with congestive heart failure depend on the method used to adjust for severity. Ann Intern Med. 2000;133(1):10-20. [pmid: 10877735].
38 Hofer TP, Hayward RA, Greenfield S, Wagner EH, Kaplan SH, Manning WG. The unreliability of individual physician “report cards” for assessing the costs and quality of care of a chronic disease. JAMA. 1999;281(22):2098-105. [pmid: 10367820].
39 Deming W. Out of the Crisis: Quality, Productivity and Competitive Position. New York: Cambridge University Press; 1982.
40 Deming W. Sample Design in Business Research (Wiley Classics Library). Hoboken, NJ: John Wiley & Sons Inc; 1990.
41 Juran J. Quality Control Handbook. New York: McGraw-Hill; 1951.
42 Managerial Breakthrough: The Classic Book on Improving Management Performance/30th Anniversary Edition. revised ed. New York: McGraw-Hill; 1995.
43 Quality Planning and Analysis: From Product Development Through Use. 4th ed. New York: McGraw-Hill; 1993.
44 Blumenthal D, Kilo CM. A report card on continuous quality improvement. Milbank Q 1998;76(4):625–48, 511.
45 Gerowitz MB. Do TQM interventions change management culture? Findings and implications. Qual Manag Health Care. 1998;6(3):1-11. [pmid: 10182535].
46 Shortell SM, Bennett CL, Byck GR. Assessing the impact of continuous quality improvement on clinical practice: what it will take to accelerate progress. Milbank Q 1998;76(4):593–624, 510.
47 Lohr KN, Schroeder SA. A strategy for quality assurance in Medicare. N Engl J Med. 1990;322(10):707-12. [pmid: 2406600].
48 Oliveria SA, Lapuerta P, McCarthy BD, L'Italien GJ, Berlowitz DR, Asch SM. Physician-related barriers to the effective management of uncontrolled hypertension. Arch Intern Med. 2002;162(4):413-20. [pmid: 11863473].
49 Roger VL, Jacobsen SJ, Weston SA, Goraya TY, Killian J, Reeder GS, et al. Trends in the incidence and survival of patients with hospitalized myocardial infarction, Olmsted County, Minnesota, 1979 to 1994. Ann Intern Med. 2002;136(5):341-8. [pmid: 11874305].
50 Ellis P, Robinson P, Ciliska D, Armour T, Raina P, Brouwers M, et al. Diffusion and Dissemination of Evidence-based Cancer Control Interventions. Evidence Report/Technology Assessment No. 79 (Prepared by the McMaster University Evidence-based Practice Center under contract no. 290-97-0017). AHRQ Publication No. 03-E032. Rockville, MD: Agency for Healthcare Research and Quality; 2003 May.
51 Grimshaw JM, Shirran L, Thomas R, Mowatt G, Fraser C, Bero L, et al. Changing provider behavior: an overview of systematic reviews of interventions. Med Care. 2001;39(8 Suppl 2):II2-45. [pmid: 11583120].
52 Stone EG, Morton SC, Hulscher ME, Maglione MA, Roth EA, Grimshaw JM, et al. Interventions that increase use of adult immunization and cancer screening services: a meta-analysis. Ann Intern Med. 2002;136(9):641-51. [pmid: 11992299].
53 Stafford RS. Alternative strategies for controlling rising cesarean section rates. JAMA. 1990;263(5):683-7. [pmid: 2296123].
54 Weingarten SR, Henning JM, Badamgarav E, Knight K, Hasselblad V, Gano A Jr, et al. Interventions used in disease management programmes for patients with chronic illness—which ones work? Meta-analysis of published reports. BMJ. 2002;325(7370):925. [pmid: 12399340]. [pmcid: 130055].
55 Thomson O'Brien MA, Oxman AD, Davis DA, Haynes RB, Freemantle N, Harvey EL. Educational outreach visits: effects on professional practice and health care outcomes. Cochrane Database Syst Rev 2000(2):CD000409.
56 Thomson O'Brien MA, Oxman AD, Davis DA, Haynes RB, Freemantle N, Harvey EL. Audit and feedback versus alternative strategies: effects on professional practice and health care outcomes. Cochrane Database Syst Rev 2000(2):CD000260.
57 Thomson O'Brien MA, Oxman AD, Davis DA, Haynes RB, Freemantle N, Harvey EL. Audit and feedback: effects on professional practice and health care outcomes. Cochrane Database Syst Rev 2000(2):CD000259.
58 Thomson O'Brien MA, Oxman AD, Haynes RB, Davis DA, Freemantle N, Harvey EL. Local opinion leaders: effects on professional practice and health care outcomes. Cochrane Database Syst Rev 2000(2):CD000125.
59 Thomson O'Brien MA, Freemantle N, Oxman AD, Wolf F, Davis DA, Herrin J. Continuing education meetings and workshops: effects on professional practice and health care outcomes. Cochrane Database Syst Rev 2001(2):CD003030.
60 Alderson P, Bero L, Grilli R, Grimshaw J, McAuley L, Oxman A, et al., editors. Effective Practice and Organisation of Care Group. Oxford: Update Software; 2003.
61 Grimshaw JM, Thomas RE, MacLennan G, Fraser C, Ramsay CR, Vale L, et al. Effectiveness and efficiency of guideline dissemination and implementation strategies. Health Technol Assess 2004 Feb;8(6):iii–iv, 1–72.
62 Kerry SM, Bland JM. Sample size in cluster randomisation. BMJ. 1998;316(7130):549. [pmid: 9501723].
63 Kerry SM, Bland JM. The intracluster correlation coefficient in cluster randomisation. BMJ. 1998;316(7142):1455. [pmid: 9572764]. [pmcid: 1113123].
64 Campbell MK, Mollison J, Grimshaw JM. Cluster trials in implementation research: estimation of intracluster correlation coefficients and sample size. Stat Med. 2001;20(3):391-9. [pmid: 11180309].
65 Torgerson DJ. Contamination in trials: is cluster randomisation the answer?. BMJ. 2001;322(7282):355-7. [pmid: 11159665]. [pmcid: 1119583].
66 Donner A, Klar N. Issues in the meta-analysis of cluster randomized trials. Stat Med. 2002;21(19):2971-80. [pmid: 12325113].
67 Donner A, Piaggio G, Villar J. Statistical methods for the meta-analysis of cluster randomization trials. Stat Methods Med Res. 2001;10(5):325-38. [pmid: 11697225].
68 Donner A, Piaggio G, Villar J. Meta-analyses of cluster randomization trials. Power considerations. Eval Health Prof. 2003;26(3):340-51. [pmid: 12971203].
69 Localio AR, Berlin JA, Ten Have TR, Kimmel SE. Adjustments for center in multicenter studies: an overview. Ann Intern Med. 2001;135(2):112-23. [pmid: 11453711].
70 Frijling BD, Lobo CM, Hulscher ME, Akkermans RP, Braspenning JC, Prins A, et al. Multifaceted support to improve clinical decision making in diabetes care: a randomized controlled trial in general practice. Diabet Med. 2002;19(10):836-42. [pmid: 12358871].
71 Kinmonth AL, Woodcock A, Griffin S, Spiegal N, Campbell MJ. Randomised controlled trial of patient centered care of diabetes in general practice: impact on current wellbeing and future disease risk. The Diabetes Care From Diagnosis Research Team. BMJ. 1998;317(7167):1202-8. [pmid: 9794859].
72 Meigs JB, Cagliero E, Dubey A, Murphy-Sheehy P, Gildesgame C, Chueh H, et al. A controlled trial of web-based diabetes disease management: the MGH diabetes primary care improvement project. Diabetes Care. 2003;26(3):750-7. [pmid: 12610033].
73 Foy R, Eccles M, Grimshaw J. Why does primary care need more implementation research?. Fam Pract. 2001;18(4):353-5. [pmid: 11477039].
74 Grol R, Grimshaw J. From best evidence to best practice: effective implementation of change in patients' care. Lancet. 2003;362:1225-30. [pmid: 14568747].
75 Cabana MD, Rand CS, Powe NR, Wu AW, Wilson MH, Abboud PA, et al. Why don't physicians follow clinical practice guidelines? A framework for improvement.[comment]. JAMA. 1999;282(15):1458-65. [pmid: 10535437].
76 Davies P, Walker A, Grimshaw J. Theories of behaviour change in studies of guideline implementation. Proceedings of the British Psychological Society. 2003;11:120.
77 Logan J, Graham ID. The Ottawa Model of Research Use: revisions, reflections, prospects (unpublished). 2003.
78 Tiffany CR, Johnson Lutjens L. Planned change theories for nursing. Review, analysis and implications. Thousand Oaks, CA: Sage; 1997.
79 Meleis A. Theoretical nursing. Development and progress. 3rd ed. New York: Lippincott; 1997.
80 Merton R. Social theory and social structure. New York: Free Press; 1968.
81 Fawcett J. Analysis and evaluation of contemporary nursing knowledge: Nursing models and theories. Philadelphia: FA Davis; 2000.
82 Smith MJ, Liehre PR. Introduction: middle range theory and the ladder of abstraction. In: Smith MJ, Liehre PR, editors. Middle range theory for nursing. New York: Springer; 2003. p. 1–24.
83 Bacharach SB. Organizational theories: some criteria for evaluation. The Academy of Management Review. 1989;14(4):496-515.
84 Rogers E. Diffusion of innovations. 3rd ed. New York: Free Press; 1983.
85 Rogers E. Diffusion of innovations. 4th ed. New York: Free Press; 1995.
86 Lomas J. Retailing research: increasing the role of evidence in clinical services for childbirth. Milbank Q. 1993;71(3):439-475. [pmid: 8413070].
87 Lomas J. Teaching old (and not so old) docs new tricks: effective ways to implement research findings. In: Dunn E, Norton P, Stewart M, Tudiver F, Bass M, editors. Disseminating research/changing practice. Thousand Oaks, CA: Sage; 1994. p. 1–18.
88 Lomas J. Medicine in context: a neglected perspective in medical education. Acad Med. 1994;69(10 Suppl):S95-101. [pmid: 7916842].
89 Tiffany CR. Analysis of planned change theories. Nurs Manage. 1994;25:60-2. [pmid: 8108081].
90 Tiffany CR, Cheatham AB, Doornbos D, Loudermelt L, Momadi GG. Planned change theory: survey of nursing periodical literature. Nurs Manage. 1994;25(7):54-9.
91 Green L, Kreuter M, Deeds S, Patridge, K. Health education planning: a diagnostic approach. Mountain View, CA: Mayfield Publishing; 1980.
92 Green L, Kreuter M. Health promotion planning: an educational and environmental approach. Mountain View, CA: Mayfield Publishing; 1991.
93 Berwick DM. Disseminating innovations in health care.[comment]. JAMA. 2003;289(15):1969-75. [pmid: 12697800].
94 Logan J, Graham ID. Toward a comprehensive interdisciplinary model of health care research use. Sci Commun. 1998;20(2):227-46.
95 Kotler P. Social marketing of health behavior. In: Frederiksen L, Solomon L, Brehony K, editors. Marketing health behavior: principles, techniques and applications. New York: Plenum Press; 1983.
96 Soumerai SB, Avorn J. Principles of educational outreach ('academic detailing') to improve clinical decision making. JAMA. 1990;263(4):549-56. [pmid: 2104640].
97 Schroeder R, Van de Ven A, Scudder G, Rolley D. Managing innovation and change processes: findings form the Minnesota Innovation Research Program. Agribusiness Manage. 1986;2:501-523.
98 Graham K, Logan J. Using the Ottawa Model of Research Use to implement a skin care program. 2003.
99 Donabedian A. The quality of care. How can it be assessed?. JAMA. 1988;260(12):1743-8. [pmid: 3045356].
100 Ferlie EB, Shortell SM. Improving the quality of health care in the United Kingdom and the United States: a framework for change. Milbank Q. 2001;79(2):281-315. [pmid: 11439467].
101 Mittman BS, Tonesk X, Jacobson PD. Implementing clinical practice guidelines: social influence strategies and practitioner behavior change. QRB. 1992;18(12):413-22.
102 Bandura A. Self-efficacy: toward a unifying theory of behavioral change.[comment]. Psychol Rev. 1977;84(2):191-215. [pmid: 847061].
103 Ajzen I. The theory of planned behaviour. Organizational Behaviour and Human Decision Process. 1991;50:179-211.
104 Wallston K. Hocus-pocus, the focus isn't strictly on locus: Rotter's social learning theory modified for health. Cognit Ther Res. 1992;16:183-99.
105 Conner M, Norman P. Health behaviour. In: Johnston D, Johnston M, editors. Comprehensive Clinical Psychology, vol. 8: Health Psychology. Oxford: Pergamon; 1998. p.1–38.
106 Godin G, Kok G. The theory of planned behavior: a review of its applications to health-related behaviors. Am J Health Promot. 1996;11(2):87-98. [pmid: 10163601].
107 Godin G, Naccache H, Morel S, Ebacher MF. Determinants of nurses' adherence to universal precautions for venipunctures. AJIC. 2000;28(5):359-64.
108 Walker A, Grimshaw J, Armstrong E. Salient beliefs and intentions to prescribe antibiotics for patients with a sore throat. Br J Health Psychol. 2001;6:347-60. [pmid: 12614509].
109 Blackman D. Operant conditioning: an experimental analysis of behaviour. London: Methuen; 1974.
110 Gollwitzer P. Goal achievement: the role of intentions. In: Stroebe W, Hewstone M, editors. European review of social psychology. Chichester, UK: Wiley; 1993. p. 141–85.
111 Orbell S, Hodgkins S, Sheeran P. Implementation intentions and the theory of planned behaviour. Pers Soc Psychol Bull. 1997;23:945-54.
112 Mazmanian PE, Daffron SR, Johnson RE, Davis DA, Kantrowitz MP. Information about barriers to planned change: a randomized controlled trial involving continuing medical education lectures and commitment to change. Acad Med. 1998;73(8):882-6. [pmid: 9736848].
113 Prochaska JO, DiClemente CC. Stages and processes of self-change of smoking: toward an integrative model of change. J Consul Clin Psychol. 1983;51(3):390-5.
114 Prochaska JO, DiClemente CC, Velicer WF, Rossi JS. Standardized, individualized, interactive, and personalized self-help programs for smoking cessation. Health Psychol. 1993;12(5):399-405. [pmid: 8223364].
115 Reimsma R, Pattenden J, Bridle C, Sowden A, Mather L, Walker A. A systematic review of the effectiveness of interventions based on a stages to change approach to promote individual behaviour change. Health Technol Assess 2002;6(24).
116 Scott WR. Organizations: rational, natural and open systems. 4th ed. Upper Saddle River, NJ: Prentice Hill; 1998.
117 Shortell SM, Kaluzny AD. Organization theory and health care management. In: Shortell SM, Kaluzny AD, editors. Health care management: a text in organization theory and behavior. New York: John Wiley and Sons; 1988.
118 Shortell SM, Kaluzny AD. Health care management: organization, design, and behavior. 3rd ed. Albany, NY: Delmar Publishers Inc.; 1994.
119 Kaluzny AD, Hernandez SR. Organizational change and innovation. In: Shortell SM, Kaluzny AD, editors. Health care management: a text in organization theory and behavior. 2nd ed. New York: John Wiley and Sons; 1988.
120 Shortell SM, Kaluzny AD. Health care management: a text in organization theory and behavior. 2nd ed. New York: John Wiley and Sons; 1988.
121 Westphal JD, Gulati R, Shortell SM. Customization or conformity? An institutional and network perspective on the content and consequences of TQM adoption. Adm Sci Q. 1997;42(2):366-94.
122 Iles V, Sutherland K. Managing change in the NHS. Organisational change: a review for health care managers, professionals, and researchers. London: NCCSDO; 2001.
123 Shortell SM, Jones RH, Rademaker AW, Gillies RR, Dranove DS, Hughes EF, et al. Assessing the impact of total quality management and organizational culture on multiple outcomes of care for coronary artery bypass graft surgery patients. Med Care. 2000;38(2):207-17. [pmid: 10659694].
124 Fox R, Mazmanian P, Putnam R. Changing and learning in the lives of physicians. New York: Praeger; 1989.
125 Grol R. Personal paper. Beliefs and evidence in changing clinical practice. BMJ. 1997;315(7105):418-21. [pmid: 9277610]. [pmcid: 2127297].
126 Kotler P, Roberto E. Social marketing: Strategies for changing public behavior. New York: Free Press; 1989.
127 Scanlon DP, Chernew M, Doty HE. Evaluating the impact of value-based purchasing: a guide for purchasers. Rockville, MD: Agency for Healthcare Research and Quality; 2002 May. AHRQ Publication No. 02-002