# Acknowledgments

During the preparation of the series volumes, Dr. Owens, Dr. Goldstein, and Dr. Nayak were supported by the Department of Veterans Affairs.

We are grateful to our many technical experts and content reviewers for their uniformly thoughtful comments.

We give special thanks to our panel of technical advisors: Jeremy Grimshaw, MBChB, PhD, University of Ottawa, Cochrane Collaboration Effective Practice and Organisation of Care Group (EPOC); Andrew Oxman, MD, MSc, Department of Health Services Research, Norwegian Directorate for Health and Social Welfare, EPOC; Russell Glasgow, PhD, Kaiser Permanente, Colorado; Martin Eccles, MD, Centre for Health Services Research, University of Newcastle upon Tyne, EPOC; Harmon Jordan, ScD, New England Medical Center Evidence-based Practice Center; and Val Lawrence, MD, MSc, The University of Texas Health Science Center at San Antonio and South Texas Veterans Health Care System; whose attentive guidance from the beginning of the project was critical to the development of the methodology and structure for the series, and who were unstinting with their assistance under unusually tight time constraints.

We are grateful to our panel of peer reviewers: Karen Adams, Institute of Medicine; Dale Bratzler, DO, MPH, Oklahoma Foundation for Medical Quality, Inc.; Lee Green, MD, MPH, University of Michigan; Norman Kaplan, MD, University of Texas, South Western Medical Center; Jerod Loeb, PhD, Joint Commission on Accreditation of Healthcare Organizations; Brian Mittman, PhD, Center for the Study of Healthcare Provider Behavior, VA Greater Los Angeles Health Care System; Peter Rudd, MD, Stanford University School of Medicine; William Rollow, MD, Centers for Medicare & Medicaid Services; Vincenza Snow, MD, American College of Physicians; William Caplan, MD, Kaiser Permanente, Patricia Barry, MD, MPH, Merck Institute of Aging and Health; Rodney Hornbake, MD, ProHealth Physicians MSO, Inc., Somerset Family Health Care; Marc Jaffe, MD, Kaiser Permanente Care Management Institute; Michelle Wong, MPH, MPP, Kaiser Permanente Care Management Institute; and Jim Zazzali, PhD, RAND Institute; who read early drafts of the chapters and provided timely and detailed comments.

We are extremely indebted to our colleagues who worked together to develop a common approach across the clinical topics. In particular, we thank Mary Goldstein, MD, MS, Judith Walsh, MD, MPH, and Sumant Ranji, MD for sharing the wisdom they gained in researching their own topics with each others' teams.

Finally, we extend our thanks to Donna Neumark, PhD for her help in reviewing articles; Alan Bostrom, PhD for statistical analyses support; and Allan Korn, MD, FACP, Blue Cross and Blue Shield Association for providing our team with important background information and contacts.

The views expressed are those of the authors, and not necessarily those of the Department of Veterans Affairs. The technical advisors and peer reviewers are not responsible for the accuracy of any of the content of this Volume.