# Full Article Review Abstraction Forms Stages 3 and 4 (Exemplar: Diabetes)

To see the Full Article Review Abstraction Forms Stages 3 and 4 (Exemplar: Diabetes), please select the link below. This link will take you to a PDF version of the forms.

Full Article Review Abstraction Forms Stages 3 and 4 (Exemplar: Diabetes)