# Article Review Triage Forms (Exemplar: Diabetes)

To see the Article Review Triage Forms (Exemplar: Diabetes), please select the link below. This link will take youto a PDF version of the forms.

Article Review Triage Forms (Exemplar: Diabetes)