# Appendixes

Appendix A National Priority Areas Summary with Key Associated Goals

Appendix B Search Strategy Exemplar: Quality Improvement and Hypertension

Appendix C Article Review Triage Forms (Exemplar: Diabetes)

Appendix D Full Article Review Abstraction Forms Stages 3 and 4 (Exemplar: Diabetes)