# Bibliography

1 Aitkin M. Meta-analysis by random effect modelling in generalized linear models. Stat Med. Sep. 1999;18(1718):2343-51. [pmid: 10474144].
2 Allison DB, Mentore JL, Heo M, et al. Antipsychotic-induced weight gain: a comprehensive research synthesis. Am J Psychiatry. Nov. 1999;156(11):1686-96. [pmid: 10553730].
3 Arends LR, Hoes AW, Lubsen J, et al. Baseline risk as predictor of treatment benefit: three clinical meta-re-analyses. Stat Med. Dec. 2000;19(24):3497-518. [pmid: 11122510].
4 Barza M, Ioannidis JP, Cappelleri JC, et al. Single or multiple daily doses of aminoglycosides: a meta-analysis. BMJ. Feb. 1996;312(7027):338-45. [pmid: 8611830]. [pmcid: 2350289].
5 Becker BJ, Schram CM. Examining Explanatory Models Through Research Synthesis. In: Cooper H, Hedges LV, editors. The Handbook of Research Synthesis. New York: Russell Sage Foundation; 1994. p. 357–81.
6 Berkey CS, Hoaglin DC, Mosteller F, et al. A random-effects regression model for meta-analysis. Stat Med. Feb. 1995;14(4):395-411. [pmid: 7746979].
7 Berkey CS, Anderson JJ, Hoaglin DC. Multiple-outcome meta-analysis of clinical trials. Stat Med. Mar. 1996;15(5):537-57. [pmid: 8668877].
8 Berkey CS, Hoaglin DC, Antczak-Bouckoms A, et al. Meta-analysis of multiple outcomes by regression with random effects. Stat Med. Nov. 1998;17(22):2537-50. [pmid: 9839346].
9 Berlin JA, Longnecker MP, Greenland S. Meta-analysis of Epidemiologic Dose-Response Data. Epidemiology. May. 1993;4(3):218-28. [pmid: 8512986].
10 Berlin JA, Antman EM. Advantages and limitations of meta-analytic regressions of clinical trials data. Online J Curr Clin Trials 1994 Jun;Doc No 134.
11 Berlin JA, Santanna J, Schmid CH, et al. Individual Patient versus Group-level Data Meta-regressions for the Investigation of Subgroup Effects: Ecological Bias Rears its Ugly Head. Stat Med 2001. In press.
12 Bucher HC, Griffith LE, Guyatt GH. Systematic review on the risk and benefit of different cholesterol-lowering interventions. Arterioscler Thromb Vasc Biol. Feb. 1999;19(2):187-95. [pmid: 9974397].
13 Carroll RJ, Stefanski LA. Measurement error, instrumental variables and corrections for attenuation with applications to meta-analyses. Stat Med. Jun. 1994;13(12):1265-82. [pmid: 7973207].
14 Cook RJ, Walter SD. A logistic model for trend in 2 X 2 X K tables with applications to meta-analyses. Biometrics. Mar. 1997;53(1):352-7. [pmid: 9147599].
15 Cooper H, Hedges LV, editors. The handbook of research synthesis. New York, NY: Russell Sage Foundation; 1994.
16 Corrao G, Bagnardi V, Zambon A, et al. Exploring the dose-response relationship between alcohol consumption and the risk of several alcohol-related conditions: a meta-analysis. Addiction. Oct. 1999;94(10):1551-73. [pmid: 10790907].
17 Daniels MJ, Hughes MD. Meta-analysis for the evaluation of potential surrogate markers. Stat Med. Sep. 1997;16(17):1965-82. [pmid: 9304767].
18 DuMouchel WH, Herbert D. Combining information from multiple dose/time/Fractionation studies (Bayesian hierarchical meta-analysis revisited). Proceedings of the 4th International Conf. on Time, Dose and Fractionation in Radiation Oncology; 1993; Madison, WI.
19 DuMouchel WH, Harris JE. Bayes Methods for Combining the Results of Cancer Studies in Humans and Other Species. JASA. Jun. 1983;78(382):293-308.
20 DuMouchel WH, Groer PG. A Bayesian methodology for combining radiation studies. 1988. p. 348–66.
21 DuMouchel WH, Groer PG. A Bayesian methodology for scaling radiation studies from animals to man. Health Phys. 1989;57(Suppl 1):411-8. [pmid: 2606701].
22 DuMouchel WH, Waternaux C, Kinney D. Hierarchical Bayesian Linear Models for Assessing the Effect of Extreme Cold Weather on Schizophrenic Births. In: Berry DA, Stangl DK, editors. Bayesian Biostatistics. 1996.
23 DuMouchel WH. Predictive Cross-Validation of Bayesian Meta-analyses. In: Bernardo JM, Berger JO, Dawid AP, et al., editors. Bayesian Statistics 5. Oxford University Press; 1996. p. 107–27.
24 DuMouchel WH. Repeated Measures Meta-analysis. Proc. 51st Session International Statistical Institute; 1997; Istanbul, Turkey.
25 DuMouchel WH, Normand SL. Computer-modeling and Graphical Strategies for Meta-analysis. In: Stangl DK, Berry DB, editors. Meta-analysis in Medicine and Health Policy. 2000. p. 127–78.
26 Egger M, Davey Smith G, Altman DG, editors. Systematic reviews in health care: meta-analysis in context. Cornwall, UK: BMJ; 2001.
27 Fay MP, Graubard BI, Freedman LS, et al. Conditional logistic regression with sandwich estimators: application to a meta-analysis. Biometrics. Mar. 1998;54(1):195-208. [pmid: 9544516].
28 Freemantle N, Cleland J, Young P, et al. Beta Blockade after myocardial infarction: systematic review and meta regression analysis. BMJ. Jun. 1999;318(7200):1730-7. [pmid: 10381708]. [pmcid: 31101].
29 Freemantle N, Anderson IM, Young P. Predictive value of pharmacological activity for the relative efficacy of antidepressant drugs. Br J Psychiatry. Oct. 2000;177:292-302. [pmid: 11116769].
30 Frost C, Clarke R, Beacon H. Use of hierarchical models for meta-analysis: experience in the metabolic ward studies of diet and blood cholesterol. Stat Med. Jul. 1999;18(13):1657-76. [pmid: 10407236].
31 Gareen IF, Greenland S, Horgenstern H. Intrauterine Devices and Pelvic Inflammatory Disease: Meta-analyses of Published Studies, 1974-1990. Epidemiology. Sep. 2000;11(5):589-97. [pmid: 10955413].
32 Geddes J, Freemantle N, Harrison P, et al. Atypical antipyschotics in the treatment of schizophrenia: systematic overview and meta-regression analysis. BMJ. Dec. 2000;321(7273):1371-6. [pmid: 11099280]. [pmcid: 27538].
33 Gleser LJ, Olkin I. Stochastically Dependent Effect Sizes. In: Cooper H, Olkin I, editors. The Handbook of Research Synthesis. New York: Russell Sage Foundation; 1994. p. 339–55.
34 Goldstein H, Yang M. Meta-analysis using multi-level models with an application to the study of class size effects. Applied Statistics. Apr. 2000;49(3):399-412.
35 Greenland S, Robins J. Invited commentary: ecologic studies—biases, misconceptions, and counterexamples. Am J Epidemiol. Apr. 1994;139(8):747-60. [pmid: 8178788].
36 Greenwood CMT, Midgley JP, Matthews AG, et al. Statistical Issues in a Metaregression Analysis of Randomized Trials: Impact on the Dietary Sodium Intake and Blood Pressure Relationship. Biometrics. Jun. 1999;55:630. [pmid: 11318226].
37 Hasselblad V. Meta-analysis of multitreatment studies. Med Decis Making. Jan. 1998;18(1):37-43. [pmid: 9456207].
38 Hedges LV. A random effects model for effect sizes. Psychol Bull. 1983;93:388-95.
39 Hedges LV, Olkin I. Regression models in research synthesis. The American Statistician. 1983;37:137-40.
40 Hedges LV, Olkin I. Statistical methods for meta-analysis. San Diego, CA: Academic Press, Inc.; 1985.
41 Hedges LV, Vevea JL. Fixed and random-effects models in meta-analysis. Psychological Methods. 1998;3:486-504.
42 Houghton T, Freemantle N, Cleland JG. Are beta-blockers effective in patients who develop heart failure soon after myocardial infarction? A meta-regression analysis of randomised trials. Eur J Heart Fail. Sep. 2000;2(3):333-40. [pmid: 10938496].
43 Ioannidis JP, Cappelleri JC, Lau J, et al. Early or deferred zidovudine therapy in HIV-infected patients without an AIDS-defining illness. Ann Intern Med. Jun. 1995;122(11):856-66. [pmid: 7741372].
44 Ioannidis JP, Lau J. The impact of high-risk patients on the results of clinical trials. J Clin Epidemiol. Oct. 1997;50(10):1089-98. [pmid: 9368516].
45 Ioannidis JP, Lau J. Pooling research results: benefits and limitations of meta-analysis. Jt Comm J Qual Improv. Sep. 1999;25(9):462-9. [pmid: 10481815].
46 Johnson ES, Lanes SF, Wentworth CE, et al. A metaregression analysis of the dose-response effect of aspirin on stroke. Arch Intern Med. Jun. 1999;159(11):1248-53. [pmid: 10371234].
47 Jones DR. Meta-analysis of observational epidemiological studies: a review. J R Soc Med. Mar. 1992;85(3):165-8. [pmid: 1556722]. [pmcid: 1294821].
48 Kasiske BL, Kalil RS, Ma JZ, et al. Effect of antihypertensive therapy on the kidney in patients with diabetes: a meta-regression analysis. Ann Intern Med. Jan. 1993;118(2):129-38. [pmid: 8416309].
49 Larholt KM, Gelber RD. Personal communication to Morton SC. 2000. Heterogeneity in meta-analysis: A simulation study of fixed and random effect methods. Available from Dr. AR Sampson.
50 Larholt KM, Tsiatis AA, Gelber RD. Personal communication to Morton SC. 2000. Variability of Coverage Probabilities When Applying a Random Effects Methodology for Meta-analysis. Available from Dr. AR Sampson.
51 Larholt KM, Sampson AR. Effects of heteroscedasticity upon certain analyses when regression lines are not parallel. Biometrics. Jun. 1995;51(2):731-7. [pmid: 7662854].
52 Levey AS, Schmid CH, Lau J. Antilymphocyte antibodies, renal transplantation, and meta-analysis. Ann Intern Med. May. 1998;128(10):863-5. [pmid: 9599200].
53 Li Y, Powers TE, Roth HD. Random-effects linear regression meta-analysis models with application to the nitrogen dioxide health effects studies. Air Waste. Mar. 1994;44(3):261-70. [pmid: 8055217].
54 Louis TA, Zelterman D. Bayesian Approaches to Research Synthesis. In: Cooper H, Hedges LV, editors. The Handbook of Research Synthesis. New York: Russell Sage Foundation; 2000. p. 411–22.
55 McIntosh MW. The population risk as an explanatory variable in research synthesis of clinical trials. Stat Med. Aug. 1996;15(16):1713-28. [pmid: 8870154].
56 Morgenstern H. Uses of ecologic analysis in epidemiologic research. Am J Public Health. Dec. 1982;72(12):1336-44. [pmid: 7137430]. [pmcid: 1650553].
57 Morris CN, Normand SL. Hierarchical Models for Combining and for Meta-analyses. In: Bernardo JM, Berger JO, Dawid AP, et al., editors. Bayesian Biostatistcs 4. Oxford: University Press; 1992. p. 321–44.
58 Mulrow C, Cook D, editors. Systematic reviews: synthesis of best evidence for health care decisions. Philadelphia, PA: American College of Physicians; 1998.
59 Pauler DK, Wakefield J. Modeling and Implementation Issues in Bayesian and Meta-analysis. In: Stangl DK, Berry DB, editors. Meta-analysis in Medicine and Health Policy. New York: Marcel Dekker, Inc.; 2000. p. 205–30.
60 Perry BH, Sampson AR, Schwab BH, et al. Personal communication to Morton SC. 2000. A meta-analytic approach to an integrated summary of efficacy: A case study of becaplermin gel. Available from Dr. AR Sampson.
61 Pladevall-Vila M, Delclos GL, Varas C, et al. Controversy of oral contraceptives and risk of rheumatoid arthritis: meta-analysis of conflicting studies and review of conflicting meta-analyses with special emphasis on analysis of heterogeneity. Am J Epidemiol. Jul. 1996;144(1):1-14.
62 Platt RW, Leroux BG, Breslow N. Generalized linear mixed models for meta-analysis. Stat Med. Mar. 1999;18(6):643-54. [pmid: 10204195].
63 Prevost TC, Abrams KR, Jones DR. Hierarchical models in generalized synthesis of evidence: an example based on studies of breast cancer screening. Stat Med. Dec. 2000;19(23):3359-76. [pmid: 11122501].
64 Raudenbush SW. Random Effects Models. In: Cooper H, Hedges LV, editors. The Handbook of Research Synthesis. New York: Russell Sage Foundation; 1994. p. 301–21.
65 Rimm EB, Williams P, Fosher K, et al. Moderate alcohol intake and lower risk of coronary heart disease: meta-analysis of effects on lipids and haemostatic factors. BMJ. Dec. 1999;319(7224):1523-8. [pmid: 10591709]. [pmcid: 28294].
66 Schmid CH, Lau J, McIntosh MW, et al. An empirical study of the effect of the control rate as a predictor of treatment efficacy in meta-analysis of clinical trials. Stat Med. Sep. 1998;17(17):1923-42. [pmid: 9777687].
67 Schmid CH. Exploring Heterogeneity in Randomized Trials Via Meta-analysis. Drug Information Journal. 1999;33:211-24.
68 Sharp SJ, Thompson SG, Altman DG. The relation between treatment benefit and underlying risk in meta-analysis. BMJ. Sep. 1996;313(7059):735-8. [pmid: 8819447]. [pmcid: 2352108].
69 Sharp SJ. Meta-analysis regression. STATA Technical Bulletin. 1998;42:16-22.
70 Sharp SJ, Thompson SG. Analysing the relationship between treatment effect and underlying risk in meta-analysis: comparison and development of approaches. Stat Med. 2000;19:3251-74. [pmid: 11113958].
71 Shea S, DuMouchel WH, Bahamonde L. A meta-analysis of 16 randomized controlled trials to evaluate computer-based clinical reminder systems for preventive care in the ambulatory setting. J Am Med Inform Assoc. Nov. 2000;3(6):399-409. [pmid: 8930856].
72 Smith TC, Spiegelhalter DJ, Thomas A. Bayesian approaches to random-effects meta-analysis: a comparative study. Stat Med. Dec. 1995;14(24):2685-99. [pmid: 8619108].
73 Smith TC, Abrams KR, Jones DR. Hierarchical Models in Generalised Synthesis of Evidence: An Example Based on Studies of Breast Cancer Screening. 16th International Society for Clinical Biostatistics Conference; 1995 Jul 31; Barcelona, Spain. Leicester (UK): University of Leicester; 1995. p. 3–32.
74 Stuck AE, Siu AL, Wieland GD, et al. Comprehensive geriatric assessment: a meta-analysis of controlled trials. Lancet. Oct. 1993;342(8878):1032-6. [pmid: 8105269].
75 Sutton AJ, Abrams KR, Jones DR, Sheldon TA, Song F; Methods for Meta-Analysis in Medical Research. Chichester, UK: John Wiley & Sons; 2000. Wiley Series in Probability and Statistics.
76 Sutton AJ, Jones DR, Abrams KR, et al. Systematic reviews and meta-analysis: a structured review of the methodological literature. J Health Serv Res Policy. Jan. 1999;4(1):49-55. [pmid: 10345567].
77 Thompson SG, Smith TC, Sharp SJ. Investigating underlying risk as a source of heterogeneity in meta-analysis. Stat Med. Dec. 1997;16(23):2741-58. [pmid: 9421873].
78 Thompson SG, Sharp SJ. Explaining heterogeneity in meta-analysis: a comparison of methods. Stat Med. Oct. 1999;18(20):2693-708. [pmid: 10521860].
79 Turner RM, Omar RZ, Yang M, et al. A multilevel model framework for meta-analysis of clinical trials with binary outcomes. Stat Med. Dec. 2000;19(24):3417-32. [pmid: 11122505].
80 Viswesvaran C, Sanchez JI. Moderator Search in Meta-analysis: A Review and Cautionary Note on Existing Approaches. Educational and Psychological Measurement. Feb. 1998;58(1):77-87.
81 Walter SD. Variation in baseline risk as an explanation of heterogeneity in meta-analysis. Stat Med. Dec. 1997;16(24):2883-900. [pmid: 9483721].
82 Wieland D, Stuck AE, Siu AL, et al. Meta-analytic methods for health services research—an example from geriatrics. Eval Health Prof. Sep. 1995;18(3):252-82. [pmid: 10145078].
83 Zeegers MPA, Tan FES, Dorant E, et al. The impact of characteristics of cigarette smoking on urinary tract cancer risk, a meta-analysis of epidemiologic studies. Cancer. Aug. 2000;89(3):630-9. [pmid: 10931463].
84 Zhong L, Goldberg MS, Parent ME, et al. Exposure to environmental tobacco smoke and the risk of lung cancer: a meta-analysis. Lung Cancer. Jan. 2000;27(1):3-18. [pmid: 10672779].
85 Zhou XH, Brizendine EJ, Pritz MB. Methods for combining rates from several studies. Stat Med. Mar. 1999;18(5):557-66. [pmid: 10209811].