# References

1 Colditz GA, Burdick E, Mosteller F. Heterogeneity in meta-analysis of data from epidemiologic studies: a commentary. Am J Epidemiol. 1995;142(4):371-382. [pmid: 7625401].
2 Moher D, Chalmers TC, Cook DJ, Eastwood S, Olkin I, Drummond R, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].
3 Stroup DF, Berlin JA, Morton SC, Olkin I, Williamson GD, Rennie D, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. 2000;283(15):2008-2012. [pmid: 10789670].
4 Thompson SG. Controversies in meta-analysis: the case of the trials of serum cholesterol reduction. Stat Methods Med Res. 1993;2(2):173-192. [pmid: 8261257].
5 Hedges LV, Olkin I. Statistical methods for meta-analysis. San Diego, CA: Academic Press, Inc.; 1985.
6 Hardy RJ, Thompson SG. Detecting and describing heterogeneity in meta-analysis. Stat Med. 1998;17(8):841-856. [pmid: 9595615].
7 Laird NM, Mosteller F. Some statistical methods for combining experimental results. Int J Technol Assess Health Care. 1990;6(1):5-30. [pmid: 2361819].
8 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
9 Morgenstern H. Uses of ecologic analysis in epidemiologic research. Am J Public Health. 1982;72(12):1336-1344. [pmid: 7137430]. [pmcid: 1650553].
10 Berlin JA, Antman EM. Advantages and limitations of metaanalytic regressions of clinical trials data. Online J Curr Clin Trials 1994;Doc No 134.
11 Berlin JA, Santanna J, Schmid CH, Szczech LA, Feldman HI. Individual patient versus group-level data metaregressions for the investigation of subgroup effects: ecological bias rears its ugly head. Stat Med. 2002;21(2):371-387. [pmid: 11813224].
12 Stuck AE, Siu AL, Wieland GD, Adams J, Rubenstein LZ. Comprehensive geriatric assessment: a meta-analysis of controlled trials. Lancet. 1993;342(8878):1032-1036. [pmid: 8105269].
13 Berkey CS, Hoaglin DC, Mosteller F, Colditz GA. A random-effects regression model for meta-analysis. Stat Med. 1995;14(4):395-411. [pmid: 7746979].
14 McIntosh MW. The population risk as an explanatory variable in research synthesis of clinical trials. Stat Med. 1996;15(16):1713-1728. [pmid: 8870154].
15 Schmid CH, Lau J, McIntosh MW, Cappelleri JC. An empirical study of the effect of the control rate as a predictor of treatment efficacy in meta-analysis of clinical trials. Stat Med. 1998;17(17):1923-1942. [pmid: 9777687].
16 DuMouchel WH. Bayesian Meta-analysis. In: Berry DA. Statistical Methodology in the Pharmaceutical Sciences. New York: Marcel Dekker; 1999.
17 Louis TA, Zelterman D. Bayesian Approaches to Research Synthesis. In: Cooper H, Hedges LV. The Handbook of Research Synthesis. New York: Russell Sage Foundation; 2000. p. 411–422.
18 Smith TC, Spiegelhalter DJ, Thomas A. Bayesian approaches to random-effects meta-analysis: a comparative study. Stat Med. 1995;14(24):2685-2699. [pmid: 8619108].
19 Theil H. Principles of Econometrics. New York: John Wiley and Sons; 1971.
20 Hasselblad V. Meta-analysis of multitreatment studies. Med Decis Making. 1998;18(1):37-43. [pmid: 9456207].
21 Schmid CH. Exploring heterogeneity in randomized trials via meta-analysis. Drug Inf J. 1999;33:211-224.
22 Mantel N, Haenszel W. Statistical aspects of the analysis of data from retrospective studies of disease. J Natl Cancer Inst. 1958;22(4):719-748. [pmid: 13655060].
23 SAS/STAT [computer program]. Version 8. Cary, NC: SAS Institute Inc.; 1999.
24 Stata Statistical Software: Release 6.0 [computer program]. Version 6.0. College Station, TX: Stata Corporation; 1999.
25 Sharp SJ. Meta-analysis regression. STATA Technical Bulletin. 1998;42:16-22.
26 S-PLUS [computer program]. Version 6.0. Seattle, WA: Data Analysis Division, MathSoft Inc.; 2000.
27 Shekelle PG, Morton SC, Maglione M, et al. Ephedra and ephedrine for weight loss and athletic performance enhancement: clinical efficacy and side effects. Evidence Report/Technology Assessment No. 76 (Prepared by the Southern California Evidence-Based Practice Center under Contract No. 290-97-0001). AHRQ Publication No. 03-E022. Rockville, MD: Agency for Healthcare Research and Quality. March 2003.
28 Shekelle PG, Hardy ML, Morton SC, Maglione M, Mojica WA, Suttorp MJ, et al. Efficacy and safety of ephedra and ephedrine for weight loss and athletic performance: a meta-analysis. JAMA. 2003;289(12):1537-45. [pmid: 12672771].
29 Assendelft WJ, Morton SC, Yu EI, Suttorp MJ, Shekelle PG. Spinal manipulative therapy for low back pain. Ann Intern Med. 2003;138(11):871-881. [pmid: 12779297].