# Acknowledgments

We gratefully acknowledge the participation and constructive feedback provided by these expert panelists:

- Dr. Jesse Berlin, University of Pennsylvania School of Medicine
- Dr. William DuMouchel, AT&T Research
- Dr. Vic Hasselblad, Duke Clinical Research Institute
- Dr. Joseph Lau, Division of Clinical Care Research, New England Medical Center
- Dr. Thomas Louis, RAND, Washington, DC
- Dr. Martin McIntosh, Biostatistics Department, University of Washington and Fred Hutchinson Cancer Research Center
- Dr. Ingram Olkin, Department of Statistics, Stanford University
- Dr. Allan Sampson, Department of Statistics, University of Pittsburgh
- Dr. Chris Schmid, Tufts University School of Medicine, New England Medical Center

Dr. Jesse Berlin from the University of Pennsylvania School of Medicine and Dr. Thomas Louis from RAND (now at Johns Hopkins) reviewed the draft report. In addition, Southern California EPC staff not on the study team also reviewed the draft report. We gratefully acknowledge the assistance of these referees.

Note : Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.