# Objectives and Key Questions of the Expert Panel Meeting

## Objectives of the Meta-regression Meeting

Our meeting objectives are to

a Obtain the reaction of the experts to our research so far, and their suggestions on how to proceed both in terms of the meta-regression topic and future methods topics.
b Answer the key questions described below.
c Stimulate a dialogue of the potentials and limitations of meta-regression to inform the evidence-based practice of medicine.

## Key Questions to Address At the Meeting

[underlined: Quantifying Heterogeneity]

1. Is the quantification of heterogeneity important?

2. If the quantification is important, how should it be done in different circumstances?

3. What, if any, is the role of formal statistical testing for heterogeneity?

[underlined: Accounting For and Understanding Heterogeneity]

4. Is the quantification of heterogeneity sufficient, or does one need to account for (incorporate) it?

5. Is accounting for heterogeneity sufficient, or does one need to understand its causes?

6. What methods should be used to account for and/or understand heterogeneity in different settings?

[underlined: Regarding Meta-regression]

7. Which meta-regression approaches should be used in which circumstances?

8. Are there meta-regression “best practices,” and do they vary by situation?

9. How should meta-regression results be reported and interpreted?

10. How does meta-regression compare to other common meta-analysis approaches (e.g., constructing random effects estimates within separate study strata)?

11. What are the key concerns about meta-regression?

12. What research needs to be conducted to improve the application of meta-regression?

13. How does meta-regression of study-level statistics relate to modeling patient-level data?

[underlined: Regarding Future Work]

In the Southern California Evidence-Based Practice Center's role as technical support to the National Center for Complementary and Alternative Medicine, we are investigating methodological research topics. Our first topic is the subject of this report: meta-regression. We'd like your guidance regarding which methodological research topic we should pursue next, and what methodology should be used (e.g., an expert panel, simulation, etc.)? Given our work in this first year, we now feel that continued investigation of meta-regression might be the most fruitful course. We had originally proposed quality assessment of observational studies as our next topic but several research groups are already working on this topic. Conceivably we could contribute by convening an expert panel akin to the QUORUM ^2^ or MOOSE ^3^ efforts.