# Expert Panel Meeting Agenda

9:00 am | Welcome and Overview
9:30 am | Unifying Notation for Models | John Adams
10:00 am | Meta-regression by Example | Vic Hasselblad
10:25 am | Control Rate Models | Chris Schmid
10:50 am | BREAK
11:05 am | Bayesian Meta-analysis | Tom Louis
11:30 am | Preliminary Simulation Results | John Adams
12:00 pm | Lunch
1:00 pm | Methodological Challenges in Meta-regression | Jesse Berlin
| Discussion
3:00 pm | BREAK
3:15 pm | Focus on Key Questions | Sally Morton
4:30 pm | Future Work | Sally Morton
5:00 pm | Adjourn