# List of Southern California Evidence-Based Practice Center Attendees at the Expert Panel Meeting

Dr. John Adams

Dr. Ian Coulter

Dr. Mary Hardy

Dr. Sally Morton

Ms. Elizabeth Roth

Dr. Paul Shekelle

Ms. Marika Suttorp