# Expert Panel and Acknowledgements

Dr. Jesse Berlin, University of Pennsylvania School of Medicine

Dr. William DuMouchel, AT&T Research

Dr. Vic Hasselblad, Duke Clinical Research Institute

Dr. Joseph Lau, Division of Clinical Care Research, New England Medical Center

Dr. Thomas Louis, RAND, Washington, DC

Dr. Martin McIntosh, Biostatistics Department, University of Washington and Fred Hutchinson Cancer Research Center

Dr. Ingram Olkin, Department of Statistics, Stanford University

Dr. Allan Sampson, Department of Statistics, University of Pittsburgh

Dr. Chris Schmid, Tufts University School of Medicine, New England Medical Center

We gratefully acknowledge the participation of and constructive feedback by these expert panelists. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

Dr. Jesse Berlin from the University of Pennsylvania School of Medicine, and Dr. Thomas Louis from RAND (now at Johns Hopkins) reviewed the draft report. In addition, Southern California Evidence-based Practice Center staff not on the study team also reviewed the draft report. We gratefully acknowledge the assistance of these referees. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.