# Appendixes

Appendix A Expert Panel and Acknowledgements

Appendix B List of Southern California Evidence-Based Practice Center Attendees at the Expert Panel Meeting

Appendix C Expert Panel Meeting Agenda

Appendix D Objectives and Key Questions of the Expert Panel Meeting

Appendix E Responses to Referees