# Exhibit A

In Chapter 1 we briefly discussed how the updates and targets are calculated. This exhibit contains a detailed explanation of how the update and Sustainable Growth Rate were calculated for 2002. However, it is important to note that the system of updates and targets used in Medicare has changed over time, so the calculation of the updates and SGR in 2002 is somewhat different from the procedures used between 1993 and 1998. The MVPS was used prior to 1998: it set targets based on historical cost increases and compared target growth two years prior to actual growth in setting the performance update factor. The BBA 1997 created the SGR which uses GDP growth in setting targets and compares cumulative growth in expenditures to a cumulative target. The BBA also limited the performance adjustment factor to a range between negative 7 and positive 3 percent. Finally, various changes were introduced by the Balanced Budget Reconciliation Act 1999 including a shift to a calendar year rather than a fiscal year timeframe and mandated retrospective corrections of estimates made before the beginning of the year to reflect actual data.