# References

American Medical Association. Medicare RBRVS: The Physician's Guide. Chicago: American Medical Association, 2001.
Board of Committee on Ways and Means. 1998 Green book: Background material and data on programs within the jurisdiction of the Committee on Ways and Means. Washington DC: US Government Printing Office, 1998.
Board of Committee on Ways and Means. 2000 Green book: Background material and data on programs within the jurisdiction of the Committee on Ways and Means. Washington DC: US Government Printing Office, 2000.
Board of Trustees Federal Supplementary Medical Insurance Trust Fund. The 2000 Annual Report of the Board of Trustees of the Federal Supplementary Medical Insurance Trust Fund. Washington DC: US Government Printing Office, 2000.
Congressional Budget Office. Trends in Health Care Spending by the Private Sector. Washington DC: Congressional Budget Office, 1997.
Cowan CA, et al. National Health Expenditures, 1999. Health Care Financing Review. 2001;22(4):102.
Duan N, et al. A comparison of alternative models for the demand of medical care. Journal of Business and Economic Statistics. 1983;1(2):115-26.
Federal Register September 4, 1990 Volume 55, No. FR 36178.
Final Rule, Federal Register Vol. 56, No. 227, Monday, November 25, 1991.
Final Notice, Federal Register, Vol. 57, No. 228. Wednesday, November 25, 1992.
Final Notice with Comment Period, Federal Register, Vol. 58, No. 230, Thursday, December 2, 1993.
Final Notice, Federal Register, Vol. 59, No. 235, Thursday, December 8, 1994.
Final Notice, Federal Register, Vol. 60, No. 236, Friday, December 8, 1995.
Final Notice, Federal Register, Vol. 61, No. 227, Friday, November 22, 1996.
Final Notice, Federal Register, Vol. 62, No. 211, Friday, October 31, 1997.
Notice with Comment Period, Federal Register, Vol. 63. No. 211, Monday, November 2, 1998.
Goldman DP, Smith JP. Methodological biases in estimating the burden of out-of-pocket expenses. Health Serv Res. 2001;35(6):1357-64. [pmid: 11221824]. [pmcid: 1089195].
Health Care Financing Administration. 35-Year Anniversary Chart Book [Web Page]. 2000; Available at http://www.hcfa.gov.
Health Care Financing Administration. Estimated Sustainable Growth Rate and Conversion Factor, for Medicare Payments to Physician in 2001 [Web Page]. 2000; Available at http://www.hcfa.gov.
Hurd MD, McGarry K. Medical insurance and the use of health care services by the elderly. J Health Econ. Apr. 1997;16(2):129-54. [pmid: 10169091].
Lillard LA, et al. Insurance coverage for prescription drugs: effects on use and expenditures in the Medicare population. Med Care. Sep. 1999;37(9):926-36. [pmid: 10493470].
Manning WG, et al. Estimating log models: to transform or not to transform?. J Health Econ. Jul. 2001;20(4):461-94. [pmid: 11469231].
Medicare and Medicaid statistical supplement. Health Care Financ Rev Statistical Suppl 1992.
Medicare and Medicaid statistical supplement. Health Care Financ Rev Statistical Suppl 1994.
Medicare and Medicaid statistical supplement. Health Care Financ Rev Statistical Suppl 1995.
Medicare and Medicaid statistical supplement. Health Care Financ Rev Statistical Suppl 1996.
Medicare and Medicaid statistical supplement. Health Care Financing Review, 2001.
MedPAC [Medicare Payment Advisory Commission]. Report to the Congress: Medicare Payment Policy. Vol. 2 Mar 1998.
MedPAC [Medicare Payment Advisory Commission]. Report to the Congress: Medicare Payment Policy. Mar 1999.
MedPAC [Medicare Payment Advisory Commission]. Report to the Congress: Medicare Payment Policy. Mar 2000.
MedPAC [Medicare Payment Advisory Commission]. Report to the Congress: Medicare Payment Policy. Nov 2000.
MedPAC [Medicare Payment Advisory Commission]. Report to the Congress: Medicare Payment Policy. Mar 2001.
Moon M. Beneath the Averages: An Analysis of Medicare and Private Expenditures. Henry J Kaiser Family Foundation, 1999.
Physician Payment Review Commission. Fee update and Medicare Volume Performance Standards for 1995. Washington, DC: Physician Payment Review Commission, 1994a.
Physician Payment Review Commission. Annual Report to Congress. Washington, DC, 1994b.
Physician Payment Review Commission. Annual Report to Congress. Washington, DC, 1995.
Statistical Abstract of the United States, Various Issues, 1993-2000.
Welch PW. What does Medicare pay for? Disentangling the flow of funds to health care providers. Health Affairs. 1998;17(4):184-97. [pmid: 9691562].