# Total Actual RVU Use by Beneficiary Age/Gender Categories, 1993 and 1998

Age | Female | Male | Total
1993 RVUs
< 65 RVUs | 36.59 | 33.16 | 34.52
< 65 observations | 592 | 940 | 1,532
65–69 years RVUs | 31.09 | 33.63 | 32.25
65–69 observations | 968 | 855 | 1,823
70–74 years RVUs | 37.55 | 38.66 | 38.02
70–74 years observations | 994 | 749 | 1,743
75–79 years RVUs | 41.16 | 45.77 | 43.02
75–79 years observations | 967 | 670 | 1,637
80–84 years RVUs | 37.48 | 49.50 | 41.74
80–84 years observations | 1,032 | 577 | 1,609
85+ years RVUs | 41.05 | 42.35 | 41.46
85+ years observations | 863 | 420 | 1,283
Total RVUs | 37.15 | 39.37 | 38.10
Total observations | 5,416 | 4,211 | 9,627
1998 RVUs (in 1998 schedule)
< 65 RVUs | 48.59 | 37.16 | 42.13
< 65 observations | 620 | 785 | 1,405
65–69 years RVUs | 31.29 | 43.36 | 36.81
65–69 observations | 751 | 651 | 1,402
70–74 years RVUs | 48.26 | 49.18 | 48.67
70–74 years observations | 999 | 839 | 1,838
75–79 years RVUs | 54.21 | 52.26 | 53.40
75–79 years observations | 913 | 659 | 1,572
80–84 years RVUs | 59.84 | 78.64 | 66.65
80–84 years observations | 955 | 560 | 1,515
85+ years RVUs | 56.19 | 59.45 | 57.23
85+ years observations | 851 | 403 | 1,254
Total RVUs | 49.11 | 50.91 | 49.89
Total observations | 5,089 | 3,897 | 8,986