# Actual Characteristics of the 1993 FFS, 1993 HMO, 1998 FFS, and 1998 HMO Samples

| 1993 Characteristics (%) | | 1998 Characteristics (%) | | RVU Model Regression Coefficient
| FFS Proportion | HMO Proportion | FFS Proportion | HMO Proportion
65–69 years* | 23.6 | 27.4 | 19.8 | 27.6 | 4.32
70–74 years* | 26.0 | 29.1 | 24.1 | 24.3 | 8.84
75–79 years* | 19.4 | 18.8 | 20.1 | 21.0 | 8.21
80–84 years* | 12.8 | 13.1 | 13.9 | 11.9 | 0.1
85+ years* | 9.2 | 7.5 | 10.3 | 8.5 | -1.41
< 65 years | 9.12 | 4.23 | 11.8 | 6.74 | ne
Male | 42.6 | 43.6 | 43.3 | 44.5 | 2.68
65–69 & male | 10.8 | 11.6 | 9.1 | 12.9 | 1.39
70–74 & male | 11.1 | 13.6 | 10.9 | 10.4 | -2.09
75–79 & male | 7.8 | 7.3 | 8.3 | 8.9 | 3.19
80–84 & male | 4.5 | 5.4 | 5.1 | 5.2 | 10.67
85+ & male | 2.9 | 2.8 | 3.3 | 3.1 | 0.15
High school education or less | 74.89 | 28.95 | 70.49 | 68.06 | ne
> High school education* | 25.1 | 29.0 | 29.5 | 31.9 | 4.02
Medicaid* | 12.8 | 0.0 | 14.6 | 0.0 | 17.8
Private supplement* | 74.6 | 100.0 | 73.7 | 100.0 | 15.49
Drug coverage* | 50.9 | 67.4 | 63.0 | 91.4 | -1.16
No supplement | 12.6 | 0 | 11.72 | 0 | ne
Urban residence* | 72.2 | 94.9 | 70.3 | 94.1 | 8.45
Northeast | 21.79 | 11.01 | 21.27 | 21.39 | ne
Midwest ^§^ | 24.8 | 16.3 | 23.2 | 22.4 | -0.63
South ^§^ | 36.9 | 18.1 | 36.1 | 34.7 | -4.59
West ^§^ | 15.3 | 54.5 | 17.9 | 20.3 | -1.84
Other^§^ | 1.3 | 0.1 | 1.5 | 1.2 | -4.07
0 ADLs | 68.23 | 74.55 | 70.86 | 76.33 | ne
1–2 ADLs | 20.5 | 18.6 | 19.1 | 16.5 | 0.4
3+ ADLs | 11.2 | 6.8 | 10.2 | 7.2 | 6.02
0 IADLs | 60.30 | 68.21 | 62.73 | 71.26 | ne
1–2 IADLs | 25.5 | 22.6 | 23.7 | 20.6 | 15.09
3+ IADL | 14.2 | 9.2 | 13.6 | 8.2 | 21.8
Ever smoked | 61.3 | 63.6 | 60.4 | 64.8 | 1.32
Hardening of the arteries | 15.2 | 13.0 | 12.3 | 10.7 | 4.53
Hypertension | 53.7 | 52.0 | 55.5 | 54.5 | 3.97
Myocardial infarction^§^ | 15.7 | 12.2 | 14.8 | 13.8 | 12.11
Angina pectoris/CHD | 15.7 | 14.0 | 15.0 | 13.8 | 5.2
Other heart condition^¥^ | 28.9 | 26.9 | 28.8 | 24.8 | 7.45
Stroke/brain hemorrhage | 10.8 | 8.8 | 11.0 | 9.7 | -6.93
Other cancer (not below) | 6.9 | 5.7 | 5.4 | 5.7 | 9.94
Skin cancer | 16.2 | 16.7 | 17.9 | 16.1 | 5.52
Lung cancer | 1.0 | 0.2 | 1.1 | 1.0 | 56.95
Colon cancer | 2.9 | 3.1 | 2.5 | 2.6 | 19.55
Breast cancer ^¥^ | 4.2 | 5.8 | 4.1 | 5.0 | 13.99
Prostate cancer ^¥^ | 2.2 | 2.2 | 3.0 | 3.9 | 25.49
Diabetes | 17.0 | 16.3 | 16.1 | 17.1 | 8.13
Arthritis | 59.5 | 55.9 | 60.2 | 59.4 | 3.52
Alzheimer's | 1.7 | 1.2 | 2.4 | 2.4 | -7.57
Mental disorder* | 6.3 | 3.6 | 7.9 | 4.5 | 2.41
Osteoporosis^¥^ | 9.7 | 11.1 | 14.0 | 10.6 | -3.51
Broken hip^¥^ | 3.9 | 3.2 | 4.6 | 2.9 | 12.98
Parkinson's^§^ | 1.7 | 0.7 | 1.5 | 1.5 | -5.45
Emphysema, asthma, COPD | 14.7 | 15.1 | 15.4 | 13.7 | 1.51
Decedent^¥^ | 3.9 | 2.3 | 3.5 | 2.3 | 43.75
Without any conditions | 9.38 | 10.71 | 8.40 | 9.36 | ne

* = significant between FFS and HMO in both years.

§ = significant between FFS and HMO only in 1993.

¥ = significant between FFS and HMO only in 1998.

ne = no coefficient estimate.

ADLs = activities of daily living.

IADLs = instrumental activities of daily living.

CHD = chronic heart disease.

COPD = chronic obstructive pulmonary disease.