# 1993 Two-part Model Estimation Results

| Probit Model on Any Use | | GLM Model on Use Given Any Use
| Coefficient | Robust Standard Error | Coefficient | Semi-Robust Standard Error
65–69 years | -0.09 | 0.11 | -0.01 | 0.10
70–74 years | 0.11 | 0.11 | 0.11 | 0.10
75–79 years | 0.16 | 0.11 | 0.09 | 0.10
80–84 years | 0.26* | 0.12 | -0.08 | 0.09
85+ years | 0.01 | 0.12 | -0.05 | 0.13
Male | -0.30* | 0.10 | 0.14 | 0.13
65–69 & male | 0.08 | 0.13 | 0.07 | 0.16
70–74 & male | -0.01 | 0.14 | -0.11 | 0.15
75–79 & male | 0.14 | 0.14 | 0.05 | 0.16
80–84 & male | 0.11 | 0.15 | 0.22 | 0.15
85+ & male | 0.50* | 0.16 | -0.04 | 0.19
> High school education | 0.12* | 0.05 | 0.06 | 0.05
Medicaid | 0.51* | 0.09 | 0.37* | 0.09
Private supplement | 0.69* | 0.06 | 0.30* | 0.07
Drug coverage | 0.01 | 0.05 | -0.05 | 0.05
Urban residence | 0.05 | 0.05 | 0.22* | 0.05
Midwest | -0.01 | 0.06 | -0.02 | 0.06
South | -0.08 | 0.06 | -0.08** | 0.05
West | -0.17* | 0.07 | -0.01 | 0.06
Other | -0.22 | 0.16 | 0.06 | 0.12
1–2 ADLs | 0.02 | 0.06 | 0.03 | 0.06
3+ ADLs | 0.01 | 0.09 | 0.11 | 0.08
1–2 IADLs | 0.17* | 0.06 | 0.38* | 0.06
3+ IADL | -0.02 | 0.09 | 0.48* | 0.08
Ever smoked | -0.07 | 0.05 | 0.04 | 0.05
Hardening of the arteries | 0.07 | 0.07 | 0.11** | 0.06
Hypertension | 0.32* | 0.04 | 0.08** | 0.04
Myocardial infarction | 0.09 | 0.07 | 0.22* | 0.07
Angina pectoris/CHD | 0.15* | 0.08 | 0.11** | 0.06
Other heart condition | 0.31* | 0.06 | 0.20* | 0.05
Stroke/brain hemorrhage | -0.04 | 0.08 | -0.07 | 0.07
Other cancer (not below) | 0.11 | 0.09 | 0.29* | 0.09
Skin cancer | 0.37* | 0.07 | 0.11* | 0.05
Lung cancer | 0.54** | 0.30 | 0.87* | 0.21
Colon cancer | 0.24** | 0.14 | 0.39* | 0.11
Breast cancer | 0.31* | 0.14 | 0.37* | 0.12
Prostate cancer | 0.29** | 0.17 | 0.56* | 0.10
Diabetes | 0.48* | 0.07 | 0.11* | 0.05
Arthritis | 0.25* | 0.04 | 0.07 | 0.05
Alzheimer's | 0.27 | 0.17 | -0.08 | 0.15
Mental disorder | 0.11 | 0.09 | 0.17* | 0.08
Osteoporosis | 0.07 | 0.09 | -0.05 | 0.07
Broken hip | 0.20 | 0.13 | 0.36* | 0.18
Parkinson's | 0.39** | 0.20 | -0.12 | 0.11
Emphysema, asthma, COPD | 0.23* | 0.07 | 0.05 | 0.05
Decedent | -0.02 | 0.12 | 0.82* | 0.09
Constant | 0.14 | 0.12 | 2.56* | 0.13
| | | (1/df) deviance = 1.5625
| R^2^(pseudo) = 0.1513 | | (1/df) pearson = 3.1202
Number of observations | 9,627 | | 8,619

Note: The probability of any use was 88.7 percent. The mean of number of RVUs conditional on use was 42.97.

* significant at p< 0.05

** significant at p< 0.10

GLM = generalized linear model.

ADLs = activities of daily living.

IADLs = instrumental activities of daily living.

CHD = chronic heart disease.

COPD = chronic obstructive pulmonary disease.

Note: Omitted categories are <65 years, <65 years and male, Northeast region, zero ADLs, zero IADLs, and no self-reported conditions.