# 1993 OLS Model Estimation Results

Dependent Variable: 1993 RVUs; Mean = 38.1 | Coefficient | Robust Standard Error
65–69 years | 4.32 | 3.63
70–74 years | 8.84* | 3.89
75–79 years | 8.21** | 4.38
80–84 years | 0.10 | 3.49
85+ years | -1.41 | 6.22
Male | 2.68 | 4.48
65–69 & male | 1.39 | 5.24
70–74 & male | -2.09 | 5.51
75–79 & male | 3.19 | 6.37
80–84 & male | 10.67** | 5.87
85+ & male | 0.15 | 7.94
> High school education | 4.02** | 2.36
Medicaid | 17.80* | 4.13
Private supplement | 15.49* | 2.16
Drug coverage | -1.16 | 2.10
Urban residence | 8.45* | 1.85
Midwest | -0.63 | 3.01
South | -4.59* | 2.24
West | -1.84 | 2.78
Other | -4.07 | 4.47
1–2 ADLs | 0.40 | 2.77
3+ ADLs | 6.02 | 4.52
1–2 IADLs | 15.09* | 2.81
3+ IADL | 21.80* | 4.37
Ever smoked | 1.32 | 1.87
Hardening of the arteries | 4.53 | 3.18
Hypertension | 3.97* | 1.69
Myocardial infarction | 12.11* | 4.00
Angina pectoris/CHD | 5.20 | 3.35
Other heart condition | 7.45* | 2.41
Stroke/brain hemorrhage | -6.93* | 3.13
Other cancer (not listed below) | 9.94* | 4.55
Skin cancer | 5.52* | 2.26
Lung cancer | 56.95* | 19.33
Colon cancer | 19.55* | 6.33
Breast cancer | 13.99* | 7.02
Prostate cancer | 25.49* | 6.70
Diabetes | 8.13* | 2.56
Arthritis | 3.52** | 1.98
Alzheimer's | -7.57 | 6.00
Mental disorder | 2.41 | 3.18
Osteoporosis | -3.51 | 3.38
Broken hip | 12.98 | 9.51
Parkinson's | -5.45 | 4.69
Emphysema, asthma, COPD | 1.51 | 2.43
Decedent | 43.75* | 8.05
Constant | -11.45* | 4.77
Number of observations | 9,627
R^2^ = 0.0684

* significant at p< 0.0.5

** significant at p< 0.10

OLS = ordinary least squares.

ADLs = activities of daily living.

IADLs = instrumental activities of daily living.

CHD = chronic heart disease.

COPD = chronic obstructive pulmonary disease.

Note: Omitted categories are <65 years, <65 years and male, Northeast region, zero ADLs, zero IADLs, and no self-reported conditions.