# Appendixes

Appendix A Payment for Physicians' Services Under the Resource Based Relative Value Scale

Appendix B 1993 OLS Model Estimation Results

Appendix C 1993 Two-part Model Estimation Results

Appendix D Actual Characteristics of the 1993 FFS, 1993 HMO, 1998 FFS, and 1998 HMO Samples

Appendix E Total Actual RVU Use by Beneficiary Age/Gender Categories, 1993 and 1998

Appendix F Legislative Changes to Prices and Coverage, 1994-1998